# Appendix D Technical Expert Panel Participants

- Joseph A. Barbera, M.D., The George Washington University
  Georges Benjamin, M.D., American Public Health Association
  Paul Biddinger, M.D., Mass General Brigham
  Laura Biesiadecki, National Association of County and City Health Officials
  Jason Brown, Public Health Management Corporation
  Jack Herrmann, M.S.Ed., American Red Cross
  Richard Hunt, M.D., U.S. Department of Health and Human Services
  Mark Keim, M.D., MBA, Fairfax County Health Department
  Christine Kosmos, R.N., M.S., U.S. Centers for Disease Control and Prevention
  James Lawler, M.D., M.P.H., University of Nebraska Medical Center
  Beth Maldin Morgenthau, M.P.H., NYC Department of Health and Mental Hygiene
  Jenna Mandel-Ricci, M.P.A., M.P.H., NYC Department of Health and Mental Hygiene
  Glen Mays, Ph.D., Colorado School of Public Health
  Ali Mokdad, Ph.D., University of Washington
  Jennifer Nuzzo, Dr.PH., Brown University
  Lisa J. Peterson, Association of State and Territorial Health Officials
  Michael A. Stoto, Ph.D., Georgetown University
  Eric Toner, M.D., Johns Hopkins Center for Health Security
  Craig Vanderwagen, M.D., East West Protection, LLC
  Michael Wargo, HCA Healthcare