# Appendix C Summary of Literature Assessing the Extent to Which Preparedness Indices Predicted Outcomes During the COVID-19 Pandemic

Title | Author (date) | Tool discussed | Key findings
Examining the UK Covid-19 mortality paradox: pandemic preparedness, health-care expenditure, and the nursing workforce | Stribling et al. (2020) | Global Health Security (GHS) Index | Country-level mortality rates do not appear to be related to the GHS Index in a manner that would be expected. The top 3 scoring countries on the GHS Index (United States, United Kingdom, and the Netherlands) all have relatively high mortality rates, while Canada (ranked 5th on the GHS Index) has a moderate mortality rate, but Australia and Thailand (ranked 4th and 6th, respectively) have a very low mortality rate.
Validity of the National Health Security Preparedness Index as a predictor of excess COVID-19 mortality | Keim and Lovallo (2021) | National Health Security Preparedness Index (NHSPI) | The NHSPI tool did not appear to be a valid predictor of excess COVID-19 mortality rates for the 50 U.S. states and Puerto Rico during the first 6 months of the pandemic (March–September 2020). Researchers found a high degree of variance and poor correlation between excess COVID-19 mortality rates compared to the overall score and to the 6 individual domains in the NHSPI.
Should policy makers trust composite indices? A commentary on the pitfalls of inappropriate indices for policy formation | Kaiser et al. (2021) | GHS Index | Composite preparedness indices like the GHS have several weaknesses, which may account for the inverted relationship between predicted vs. actual performance. Weaknesses identified include an inconsistent scoring system, arbitrary weighting of indicators, inclusion of indicators with questionable validity, inability to compare scores across countries, and inability to capture political bias.
The Global Health Security index and Joint External Evaluation score for health preparedness are not correlated with countries’ COVID-19 detection response time and mortality outcome | Haider et al. (2020) | GHS Index; Joint External Evaluation (JEE) for health preparedness | The GHS index and JEE were found to be strongly correlated, but both indices had a poor correlation with countries’ COVID-19 related mortality outcomes and had low predictive value for detection response time from March 11–July 1, 2020.
Does it matter that standard preparedness indices did not predict COVID-19 outcomes? | Stoto and Nelson (2023) | GHS Index JEE for health preparedness | A country’s success in dealing with a pandemic is highly multidimensional and may be too complex to represent with a single number, as provided by the GHS and JEE. Methodological issues identified include the comparability of mortality data due to highly variable completeness and representativeness and the inability to capture variations in the presence of effective political leadership.
The Global Health Security Index is not predictive of coronavirus pandemic responses among Organization for Economic Cooperation and Development countries | Abbey et al. (2020) | GHS Index | A rank-based analysis measuring total cases, total deaths, recovery rate, and total tests performed found a discrepancy between the GHS Index rating and the actual performance of Organization for Economic Cooperation and Development countries during the COVID-19 pandemic.
Strengthening national capacities for pandemic preparedness: A cross-country analysis of COVID-19 cases and deaths | Duong et al. (2022) | IHR-SPAR; GHS index; Universal Health Coverage Service Coverage Index; World Bank Worldwide Governance Indicator | Countries with higher GHS and IHR-SPAR scores experienced fewer reported COVID-19 cases and deaths but only for the first 8 weeks after the country’s first case (for GHS, the association was limited to countries with populations below 69.4 million). The country-level rankings from the Universal Health Coverage Service Coverage Index and Worldwide Governance Indicator were not associated with COVID-19 outcomes.
A COVID-19 lesson: Better health emergency preparedness standards are needed | Moulton (2022) | NHSPI; TFAH | High NHSPI and TFAH preparedness scores were generally, but not uniformly, associated with lower COVID-19 death rates. The measure of effectiveness of the pandemic response was measured by states’ cumulative COVID-19 deaths per 100,000 population from January 1, 2020–January 20, 2022.
Are preparedness indices reflective of pandemic preparedness? A COVID-19 reality check | Kachali et al. (2022) | IHR; GHS index | States’ reported cumulative mortality rates during the first wave of the COVID-19 pandemic (spring 2020) were primarily negatively correlated with the expected preparedness rank, according to IHR and GHS.
Comparison of COVID-19 Resilience Index and its associated factors across 29 countries during the Delta and Omicron variant periods | Huy et al. (2022) | Pandemic resilience index | Across 29 countries, the percentage of the population fully vaccinated and high government indices scores were significantly associated with a better resilience index score in both the COVID-19 Delta and Omicron periods. The pandemic resilience index combines country-level mortality, hospital occupancy, and intensive care unit occupancy rates.
Global health security preparedness and response: An analysis of the relationship between Joint External Evaluation scores and COVID-19 response performance | Nguyen et al. (2021) | JEE for health preparedness; Emergency Response Capacity Tool (ERCT) | There is low agreement between JEE scores and COVID-19 response performance, with JEE scores often trending higher. The JEE indicator “Emergency Operations Center (EOC) operating procedures and plans” had the highest agreement and predicted probability with ERCT (62 percent), and the “capacity to activate emergency operations” had the lowest predicted probability (16 percent).
The National Health Security Preparedness Index (2021 release); Note: Not peer reviewed. | Mays et al. (2021) | NHSPI | COVID-19 deaths were significantly lower in communities with higher levels of health security as measured in the index when controlling for county population size, population density, percent aged 65 years or older, percent Black, percent Hispanic, percent below poverty level, percent under age 65 without health insurance, number of nursing home residents per capita, and social vulnerability rates measured in the Community Resiliency Index, and adjusting for clustering of counties within states.

GHS = Global Health Security; IHR = International Health Regulations; NHSPI = National Health Security Preparedness Index; SPAR = States Parties Self-Assessment Annual Report; TFAH = Trust for American Health index.