# Appendix B Tools to Measure State, Local, Tribal, and Territorial Public Health and Health Care Preparedness in the United States

Tool | Type of tool | Hazard | Domain(s) | Jurisdiction level(s) | Data source | Intended users | Strengths | Weaknesses
ASPR’s Hospital Preparedness Program performance measure (https://aspr.hhs.gov/HealthCareReadiness/guidance/Documents/Updated-2019-2023-HPP-PMI-Guidance-6Jul2023-508.pdf) set (ASPR 2022) | Measure set | AH | - Foundation for Health Care and Medical Readiness; - Health Care and Medical Response Coordination; - Continuity of Health Care Service Delivery; - Medical Surge | National; HPP funding recipient (state, territorial, large local); HCC (local/substate) level | Data self-reported by funding recipients; ASPR shares data publicly | Federal officials; State and local officials; HCCs and local multi-sector coalitions; General public | Some measures are at the HCC (local) level so may be relevant and actionable for communities to use for planning | Most data are reported at the level of the funding recipient (generally state and territorial).; HCCs are not consistent sizes and are not always comparable.; Earlier assessments of the HPP measures in a 2013 GAO report noted the need for annual benchmarks to support progress over time.^a^
Assessment for Disaster Engagement with Partners Tool (ADEPT) (https://www.ncbi.nlm.nih.gov/pmc/articles/PMC4187310/) (Glik et al. 2014) | Index | AH | - Communication outreach and coordination; - Resource mobilization; - Organizational capacity building; - Partnership development and maintenance | Local | Data self-reported/ self-administered by local health departments | Local health departments | Captures valuable information on the linkages between LHDs and CBOs/FBOs for disaster information, resources, shelter, and other assistance | Evidence of the tool’s validity and predictive capacity in real-world emergencies is limited.
Community Outbreak Preparedness Index (https://copi.helunahealth.org/assets/COPI-Technical-Report.pdf) (Ghosh et al. 2023) | Index | ID | - Health-care system preparedness; - Public health system preparedness; - Access to health insurance and social safety net services; - Community factors | Local | NACHHO data; FEMA data; American Hospital Association Survey; National Provider Identifier; other sources | STLT public health officials and partners; policy makers | Fills a gap in indices specific to local agencies | The new tool is not widely validated or researched in different local contexts.
Connectivity Measurement Tool (https://www.ncbi.nlm.nih.gov/pmc/articles/PMC1847495/) (Dorn et al. 2007) | Index | AH | - System; - Coworker; - Organization; - Individual | Local (individual, organization and/or system) | Self-administered questionnaire | STLT emergency preparedness agencies and organizations | Authors believe that aggregated scores collected from specific organizations or systems provide data that can be used for comparative purposes | Self-reported data are prone to response bias.; The tool does not include an assessment of performance in relation to connectivity.
Hospital Medical Surge Preparedness Index (https://www.ncbi.nlm.nih.gov/pmc/articles/PMC7222860/) (Marcozzi et al. 2020) | Index | AH | - Staff; - Supplies; - Space; - System | Local (facility/hospital) | American Hospital Association annual survey data, U.S. Census Bureau, and the Dartmouth Atlas project | Hospital administrators; Regional and state emergency planners | Hospital-level data provide granular information that can be aggregated to inform state and regional emergency planners | The index fails to measure synergies between hospitals to improve collective response.; The index has not been validated in relation to hospital performance in the face of actual disasters.
National Health Security Preparedness Index (https://nhspi.org/explore-the-index/#methodology) | Index | AH | - Health security and surveillance; - Community planning and engagement; - Incident and information management; - Health care delivery; - Countermeasures management; - Environmental and occupational health | National; State | 64 data sources, including surveys (i.e., BRFSS, ASTHO profiles, Comprehensive Laboratory Services Survey, All-Hazards Laboratory Preparedness Survey, and others), safety inspection results, and federal administrative records | Federal, state, and local officials; Multisector coalitions; Researchers; General Public | ASTHO coordinated input from a wide range of stakeholders to develop the tool in 2013; Served as one of the first tools to assess all-hazards preparedness at the sub-national level in the United States; There is some evidence that high preparedness scores were associated with lower death rates during the COVID-19 pandemic^a,b^ | There is evidence that the NHSPI is not a valid predictor of excess COVID-19 mortality rates for 50 U.S. states and Puerto Rico during the first six months of the pandemic.^c^
Preparedness Capacity Assessment Survey (https://www.researchgate.net/publication/259315977_Improving_Public_Health_Preparedness_Capacity_Measurement_Development_of_the_Local_Health_Department_Preparedness_Capacities_Assessment_Survey) Davis et al. 2013) | Index | AH | - Surveillance and investigation; - Plans and protocols; - Workforce and volunteers; - Communication and information dissemination; - Incident command; - Legal infrastructure and preparedness; - Emergency events and exercises; - Corrective action activities | Local | Survey completed by local health departments | State and local health departments | The domains reflect the essential and vital capacities for local and state health departments to effectively build and maintain their preparedness capabilities | Data are self-reported and may contain potential response bias.; The tool is not designed for comparison across jurisdictions.
Rapid Urban Health Security Assessment (https://pubmed.ncbi.nlm.nih.gov/32546588/) (RUHSA) (Boyce and Katz 2020) | Measure set | AH | - Prevent public health emergencies; - Detect public health emergencies; - Respond to public health emergencies; - Other considerations | Local | Internal data used for self-assessment | Local government leaders and policymakers | Assesses immediate capacity to respond to disease and health threats at the local level | RUHSA is a self-assessment tool, so does not allow for comparison or benchmarking against other similar jurisdictions.; Designed specifically for urban jurisdictions, the tool is not applicable to rural jurisdictions.
Trust for America’s Health (https://www.tfah.org/wp-content/uploads/2024/03/2024-ReadyOrNot-FINAL.pdf) Ready or Not tool (McKillop 2024) | Measure set | AH | - Incident management; - Institutional quality; - Water security; - Workforce resiliency and infection control; - Countermeasure utilization; - Patient safety; - Health security surveillance; - Public health system comprehensiveness (not included in 2024 report) | National (summarizes number of states in high, medium, and low tiers); State | NHSPI data sources and state public health expenditure data collected and analyzed by TFAH | Federal, state, and local officials; general public; researchers; | Includes a narrower set of measures than NHSPI, allowing for focused attention to guide stakeholders in improvement efforts.; High TFAH preparedness scores were generally, but not uniformly, associated with lower death rates.^a^ | The tool’s narrow set of goals does not consider the full range of risks that a jurisdiction may face.

Note: Strengths and weaknesses were cited within the source for each tool, unless otherwise noted. AH = all hazards; AHA = American Hospital Association; ASPR = Administration for Strategic Preparedness and Response; ASTHO = Association of State and Territorial Health Officials; BRFSS = Behavioral Risk Factor Surveillance System; CBO = community-based organization; FBO = faith based organization; FEMA = Federal Emergency Management Agency; HCC = health care coalition; ID = infectious disease; LHD = local health department; NHSPI = National Health Security Preparedness Index; STLT = state, tribal, local, or territorial; TFAH = Trust for American Health index.

a Moulton, A.D. “A COVID-19 Lesson: Better Health Emergency Preparedness Standards Are Needed.” Health Security, vol. 20, no. 6, 2022, pp. 457–466. 10.1089/hs.2022.0037.36367989

b Mays, G., and M. Childress. “2021 Release of National Health Security Preparedness Index.” University of Colorado, Colorado School of Public Health, June 2021.

c Keim, M.E., and A.P. Lovallo. “Validity of the National Health Security Preparedness Index as a Predictor of Excess COVID-19 Mortality.” Prehospital and Disaster Medicine, vol. 36, no. 2, 2021, pp. 141–144. 10.1017/S1049023X20001521.33397547