# Appendix A Methods

The study included an environmental scan, a technical expert panel (TEP), a synthesis analysis of themes and gaps in current metrics, and a synthesis analysis of strategies to advance public health preparedness metrics. In this appendix, we describe our study methods.

## A Environmental scan

With support from our partner, MDB, Inc., we conducted an environmental scan. The primary goal of the scan was to learn about existing domestic and international public health and health-care preparedness measures, indices, and inventories (which we collectively describe as “tools”). Although the focus of this project is on domestic preparedness, the inclusion of articles focusing on global tools that assess nation-level preparedness provided valuable insights and perspectives that enhanced and broadened understanding of this topic.

We identified peer-reviewed and gray literature for the environmental scan by systematically searching PubMed and Web of Science databases and select government agency and preparedness-tool websites. We supplemented these searches with targeted Google searches. We applied the following exclusion criteria to literature returned through the searches that:

/ Focused on individual or household emergency preparedness (for example, checklists to assess emergency preparedness at the household level)
/ Focused on studies or tools that measure preparedness at the subnational level in countries outside the United States (for example, comparing disaster preparedness in French pediatric hospitals)
/ Did not focus on any phase of the emergency preparedness cycle (for example, articles describing postdisaster outcomes that did not also assess elements of prevention, protection, mitigation, response, and recovery)
/ Did not describe efforts to measure preparedness (for examples, articles describing emergency training curricula for health and public health workers)
/ Summarized after-action reports and lessons learned from individual public health agencies

Below, we describe our approaches to identifying relevant literature.

1. Searched PubMed and Web of Science for peer-reviewed journal articles: From October through December 2023, we conducted searches of PubMed and Web of Science records using search terms related to public health (and variations such as community health and population health); medical systems (including variations such as health infrastructure and hospitals); emergencies, disasters, and hazards; preparedness, readiness, resilience, and vulnerability; and measurement (including variations such as measures, scores, index, and scorecard).^13^ We restricted the PubMed and Web of Science searches to articles published after 2012 to focus on recent tools and research, and applied the exclusion criteria listed above to the returned articles.
2. Searched government agency and preparedness-tool websites: In April 2024, we conducted focused searches on the websites of key government agencies and prominent preparedness-tool websites to identify relevant publications on public health or health preparedness. We then applied the exclusion criteria described above to the returned literature. We searched webpages for the following organizations and agencies: the Centers for Disease Control and Prevention, Administration for Strategic Preparedness and Response, the Federal Emergency Management Administration, National Association of County and City Health Officials (NACCHO), the Association of State and Territorial Health Officials (ASTHO), Pan American Health Organization, National Health Security Preparedness Index (NHSPI), and Trust for America’s Health.
3. Conducted targeted Google searches: The peer-reviewed and gray literature included scoping reviews that mentioned a few U.S.-based tools that were not associated with articles returned from the searches noted above. To learn more about these tools, we conducted additional targeted Google searches using the tool name as the search term.

Initial PubMed and Web of Science searches for peer-reviewed literature returned 1,878 articles. After applying exclusion criteria, we identified 74 articles to include in the full-text review. Our searches for gray literature on federal agency websites, preparedness-tool websites, and Google yielded an additional 30 documents.

In total, we closely reviewed 104 pieces of peer-reviewed and gray literature (Exhibit A.1). From each of these articles, we extracted information identifying the tool being discussed (if any), challenges in measuring preparedness, and key findings related to measuring public health and health-care preparedness. We highlight key findings from the environmental scan in Chapter II, although we cite relevant sources throughout the report.

Exhibit A.1 Identification of literature via databases and supplemental searches

This exhibit shows the process for identifying relevant literature via databases and supplemental searches. The research team initially identified 2,568 articles through systematic searches of PubMed and Web of Science databases and 30 pieces of grey literature identified through non-systematic searches. The team removed 690 duplicate records, and then screened 1,908 record by title and abstract. The team excluded 1,727 irrelevant articles. This left 181 full-text publications, which the team assessed for eligibility. This yielded 104 publications included in the literature review.

## B Technical expert panel

Our partner, MDB, Inc., convened a technical expert panel (TEP) in January 2024, composed of 20 experts from federal agencies, public health and health-care organizations, and academia (a complete list of TEP members and their affiliations is in Appendix D). We identified TEP members with a background in public health or health preparedness, an understanding of metrics, and broad knowledge of current disaster threats. We attempted to identify a subset of TEP members who represent the perspectives of populations that are socially vulnerable, given the challenges in reaching these populations and disparities in postdisaster outcomes.

MDB conducted the two-hour TEP meeting virtually, facilitating a combination of breakout group and main group discussions. The breakout group portion of the meeting consisted of three small group discussions facilitated by MDB and Mathematica staff. Throughout the meeting, TEP members discussed (1) the strengths and weaknesses of current measures, drawing on findings from the scan and their own experiences; (2) key takeaways from the COVID-19 pandemic; and (3) considerations for future preparedness measurement efforts, including new data sources that could be captured in measures. Appendix E presents the full TEP meeting agenda.

A notetaker captured comments from TEP members, which was subsequently used for thematic analysis. We coded the findings to understand the relative frequency of different themes and the prevalence of these themes across breakout groups. Unless otherwise noted, all TEP findings and quotations included in this report were mentioned by at least three TEP members across two or more breakout groups. TEP findings are interweaved with literature findings throughout the report.

## C Analysis of themes and gaps in current preparedness metrics

Using data from the environmental scan and the TEP, we analyzed themes and gaps in current U.S. preparedness metrics related to eight characteristics (Exhibit A.2), which we summarize in Chapter II. Our approach to assessing themes and gaps varied by characteristic, as some characteristics are relevant at the tool level (for example, the types and intended users of indices) whereas others are relevant at the measure level (for example, the data source for a measure of preparedness).

Exhibit A.2 Characteristics of preparedness metrics assessed in the analysis of themes and gaps

Characteristic | Level of analysis
Types of available tools | Tool level
Purpose | Tool level
Intended users | Tool level
How metrics conceptualize preparedness | Tool and measure levels
Types of disasters addressed | Tool level
Jurisdiction levels | Tool level
Data sources | Measure level
Preparedness factors being measured | Measure level

For tool-level characteristics, we used the literature from the environmental scan to develop a de-duplicated summary table of U.S.-based preparedness tools and their characteristics (Appendix B). We defined “preparedness tools” as tools that assessed national, state, or local capacity in two or more phases of the emergency preparedness cycle (that is, prevention, protection, mitigation, response, and recovery). We did not include tools that (1) exclusively measure nation-level preparedness, (2) measure subnation level preparedness outside the United States, or (3) measure a single phase of preparedness (for example, vulnerability and resilience indices). From the 104 documents that we reviewed as part of the environmental scan, we identified 12 existing preparedness tools at the STLT (state, tribal, local, or territorial) level. Each article did not present a unique tool; many of these articles focused on the same tools and metrics (most commonly, the NHSPI). We used the summary table to describe the frequencies of tool-level characteristics across existing tools and to identify gaps in these characteristics. We synthesized these findings with others from the literature and the TEP and highlighted in the report any inconsistencies across data sources.

For measure-level characteristics, we relied on the synthesis of TEP and literature findings to identify themes and gaps. We approached the measure-level analysis this way because it was not feasible to develop a comprehensive, de-duplicated list of existing measures, given the vast number of measures across existing tools. We summarize the findings from the themes and gap analysis in Chapter II.

## D Analysis of strategies to advance preparedness measurement

To inform the analysis of strategies to advance preparedness measurement (Chapter III), we first reviewed literature on public health performance measurement to understand important attributes of metrics and the extent to which these attributes are missing from existing preparedness metrics, as identified in the gaps analysis. We then reviewed TEP findings to identify strategies the TEP members had suggested to address the gaps in existing metrics. We synthesized TEP findings with themes from the literature to develop the list of proposed strategies in Chapter III.

13 This list of search terms is not exhaustive.