# REFERENCES

3 Axis Advisors, 2023. Estimates of U.S. Brand Drug Commercial Net Prices. [Online] Available at: https://static1.squarespace.com/static/5c326d5596e76f58ee234632/t/63eaf7810ade4918ae2e6520/1676343172537/3AA+Understanding+VA+Pricing+Report+0223.pdf
46Brooklyn, n.d. How to Construct the Medicaid Drug Pricing Heat Map. [Online] Available at: https://www.46brooklyn.com/videos
Association for Accessible Medicines, 2022. The U.S. Generic & Biosimilar Medicines Savings Report, s.l.: s.n.
Beran, D., Hirsch, I. & Yudkin, J., 2018. Why are we failing to address the issue of access to insulin? A national and global perspective. Diabetes Care, 41(6), pp. 1125–1131.29784696
Berenbrok, L. . 2022. Access to community pharmacies: A nationwide geographic information systems cross-sectional analysis. Journal of the American Pharmacists Association, 62(6), pp. 1816–1822.35965233
Black, J., Hashimzade, N. & Myles, G., 2009. Oxford Dictionary of Economics. 3rd ed. Oxford, UK: Oxford University Press.
Bosworth, A. . 2022. Price Increases for Prescription Drugs, 2016-2022, Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, Department of Health and Human Services.
Burns, L., 2022. Prescription Drug Benefit Design in ERISA Health Plans. In: The Healthcare Value Chain: Demystifying the Role of GPOs and PBMs. s.l.:Palgrave Macmillan.
Centers for Medicare & Medicaid Services, 2017. Medicare Part D – Direct and Indirect Remuneration (DIR), s.l.: s.n.
Centers for Medicare & Medicaid Services, 2022. Medicaid Covered Outpatient Prescription Drug Reimbursement Information by State, s.l.: s.n.
Centers for Medicare & Medicaid Services, 2022. Medicare Program; Contract Year 2023 Policy and Technical Changes to the Medicare Advantage and Medicare Prescription Drug Benefit Programs, s.l.: Federal Register.
Cole, A., Adrian, T. & Segel, C., 2019. Value, access, and incentives for innovation: policy perspectives on alternative models for pharmaceutical rebates. Institute for Clinical and Economic Review.
Commonwealth Fund, 2019. Pharmacy Benefit Managers and Their Role in Drug Spending. [Online].
Congressional Budget Office, 2021. A Comparison of Brand-Name Drug Prices Among Selected Federal Programs, s.l.: s.n.
Congressional Budget Office, 2021. Paying for Drugs in Medicare Part D Under Current Law and Under Proposals to Redesign the Program, Washington, D.C.: Congressional Budget Office.
Congressional Budget Office, 2022. Prescription Drugs: Spending, Use, and Prices, Washington D.C.: Congressional Budget Office.
Cubanski, J., Rae, M., Young, K. & Damico, A., 2019. How Does Prescription Drug Spending and Use Compare Across Large Employer Plans, Medicare Part D, and Medicaid?, s.l.: KFF.
Dolan, R. & Tian, M., 2020. Pricing and Payment for Medicaid Prescription Drugs. [Online] Available at: https://www.kff.org/report-section/pricing-and-payment-for-medicaid-prescription-drugs-issue-brief/ [Accessed 2023].
Dusetzina, S., Conti, R., Yu, N. & Bach, P., 2017. Association of Prescription Drug Price Rebates in Medicare Part D with Patient Out-of-pocket and Federal Spending. JAMA Internal MKedicine, 177(8), pp. 1185–1188. doi: 10.1001/jamainternmed.2017.1885.
Epstein, M. . 2023. A Methodology for Estimating Medicaid and Non-Medicaid Net Prices Using Top Brand-Name Drugs, 2015-2019, Washington, DC: Urban Institute.
Eyles, M., 2022. AHIP Public Comments to FTC on Business Practices of PBMs. [Online] Available at: https://www.ahip.org/resources/ahip-public-comments-to-ftc-on-business-practices-of-pbms
Federal Insurance Office, 2022. Annual Report on the Insurance Industry, Washington, D.C.: U.S. Department of the Treasury.
Fein, A., 2017. Follow the Dollar Math: How Much Do Pharmacies, Wholesalers, and PBMs Make From a Prescription. [Online] Available at: https://www.drugchannels.net/2017/08/follow-dollar-math-how-much-do.html [Accessed 2 August 2023].
Fein, A., 2019. Drug Channels. [Online] Available at: https://www.drugchannels.net/2019/01/independent-pharmacy-economics-keep.html
Fein, A., 2019. Independent Pharmacy Economics Keep Deteriorating. [Online] Available at: https://www.drugchannels.net/2019/01/independent-pharmacy-economics-keep.html
Fein, A., 2019. The State of Retail Pharmacy: Independent Pharmacy Economics Stabilize—But Dropping, Owner Salaries Are. [Online] Available at: https://www.drugchannels.net/2019/12/the-state-of-retail-pharmacy.html [Accessed 2 August 2023].
Fein, A., 2022. Mapping the Vertical Integration of Insurers, PBMs, Specialty Pharmacies, and Providers: A 2022 Update. [Online] Available at: https://www.drugchannels.net/2022/10/mapping-vertical-integration-of.html [Accessed 6 March 2024].
Fein, A., 2022. Texas Shows Us Where PBMs’ Rebates Go (rerun). [Online] Available at: https://www.drugchannels.net/2022/12/texas-shows-us-where-pbms-rebates-go.html
Fein, A., 2023. The Top Pharmacy Benefit Managers of 2022: Market Share and Trends for the Biggest Companies. [Online] Available at: https://www.drugchannels.net/2023/05/the-top-pharmacy-benefit-managers-of.html
Feldman, R., 2020. Perverse Incentives: Why Everyone Prefers High Drug Prices – Except for Those Who Pay the Bills. Harvard Journal on Legislation, 30(30).
Feng, J. & Maini, L., 2023. Demand Inertia and the Hidden Impact of Pharmacy Benefit Managers. [Online] Available at: https://papers.ssrn.com/sol3/papers.cfm?abstract_id=3316430 [Accessed 2 August 2023].
Fuse-Brown, E. & McCuskey, E., 2020. The Implications of Rutledge v. PCMA for State Health Care Cost Regulation. Health Affairs Blog, 17 December, p. doi: 10.1377/hblog20201216.909942.
Guardado, J., 2023. Competition in Commercial PBM Markets and Vertical Integration of Health Insurers with PBMs-2023 Update. Policy Research Perspectives, American Medical Association.
Iowa Code 2023, Section 510B.1 (22, 3) , 2023. Regulation of Pharmacy Benefits Managers, §510B.1. s.l.:s.n.
Iowa Insurance Division, 2020–2023. PBM Annual Reports, s.l.: s.n.
Kakani, P., Chernew, M. & Chandra, A., 2020. Rebates in the Pharmaceutical Industry: Evidence from Medicines Sold in Retail Pharmacies in the U.S.. NBER Working Paper Series, March, Volume Working Paper 26846, pp. 1–36.
Kirzinger, A. . 2023. Public Opinion on Prescription Drugs and Their Prices. [Online] Available at: https://www.kff.org/health-costs/poll-finding/public-opinion-on-prescription-drugs-and-their-prices/
Meador, M., 2011. Squeezing the Middleman: Ending Underhanded Dealing in the Pharmacy Benefit Management Industry Through Regulation. Annals of Health Law, 20(1), pp. 77–112.21639019
Metcalf, T. & Weinberg, N., 2017. Drug Middlemen Have Slim Profit Margins-Just Ask Them. Bloomberg, 30 March.
Miller, G., Hill, S. & Ding, Y., 2019. Retail Drug Prices, Out-of-Pocket Costs, and Discounts and Markups Relative to List Prices: Trends and Differences by Drug Type and Insurance Status, 2011 to 2016, Rockville, MD: Agency for Healthcare Research and Quality.
Myshko, D., 2023. Analysis: PBMs Block Access to Lantus Biosimilars. [Online] Available at: https://www.formularywatch.com/view/analysis-pbms-block-access-to-lantus-biosimilars [Accessed 2 August 2023].
National Academy for State Health Policy, 2023. 2023 State Legislative Action to Lower Pharmaceutical Costs. [Online] Available at: https://nashp.org/2023-state-legislative-action-to-lower-pharmaceutical-costs/
National Conference of State Legislatures, 2022. State Policy Options and Pharmacy Benefit Managers (PBMs). [Online] Available at: https://www.ncsl.org/health/state-policy-options-and-pharmacy-benefit-managers
National Conference of State Legislatures, n.d. Prescription Drug State Bill Tracking Database, 2015-Present. [Online] Available at: https://www.ncsl.org/health/prescription-drug-state-bill-tracking-database-2015-present
Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health & Human Services, 2022. Report on the Affordability of Insulin, s.l.: s.n.
Organisation for Economic Cooperation and Development, 2023. Pharmaceutical spending (indicator). doi: 10.1787/998febf6-en. [Online] Available at: https://data.oecd.org/healthres/pharmaceutical-spending.htm
Parasrampuria, S. & Murphy, S., 2022. Trends in Prescription Drug Spending, 2016-2021, Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, US Department of Health and Human Services.
Park, C., 2022. Trends in Medicaid Drug Spending and Rebates, Washington D.C.: Medicaid and CHIP Payment Access Commission.
PBM Accountability Project, undated. How PBMs Make Money. [Online] Available at: https://www.pbmaccountability.org/_files/ugd/b11210_de1b94dce1c14a9ab6decc2bef5e145e.pdf?index=true
Rome, B., Egilman, A. & Kesselheim, A., 2022. Trends in prescription drug launch prices. JAMA, 21(327), pp. 2145–2147.
RxBenefits, 2020. Pass-Through vs Traditional PBM Contracts: True Numbers Comparison, s.l.: s.n.
Seeley, E., 2022. The Impact of Pharmaceutical Wholesalers on U.S. Drug Spending, New York, NY: The Commonwealth Fund.
Seeley, E. & Kesselheim, A., 2019. Pharmacy benefit managers: practices, controversies, and what lies ahead. Issue Brief (Commonw Fund), pp. 1–11.
Shepherd, J., 2019. Pharmacy benefit managers, rebates, and drug prices: conflicts of interest in the market for prescription drugs. Yale L. & Pol’y Rev., Volume 38, p. 360.
Sood, N., Mulligan, K. & Zhong, K., 2021. Do Companies in the Pharmaceutical Supply Chain Earn Excess Returns?. International Journal of Health Economics and Management, 21(1), pp. 99–114. doi: 10.1007/s10754-020-09291-1.33394339
Sood, N., Shih, T., Van Nuys, K. & Goldman, D., 2017. The Flow of Money Through the Pharmaceutical Distribution System, Los Angeles, CA: Schaeffer Center White Paper Series.
Stomberg, C., 2021. The Role of Rebates in the Pharmaceutical Industry, Washington, D.C.: American Health Law Association, Anti-trust Practice Group.
Tretina, K., 2023. How Fiduciary Duty Impacts Financial Advisors. Forbes Advisor, 17 May.
Trish, E., Van Nuys, K. & Popovian, R., 2022. U.S. Consumers Overpay for Generic Drugs, Los Angeles, CA: Schaeffer Center for Health Policy and Economics.
U.S. Department of Veterans Affairs, Office of Procurement, Acquisition and Logistics, 2023. Pharmaceutical Prices: Pricing Data. s.l.:s.n.
United States Government Accountability Office, 2019. Use of Pharmacy Benefit Managers and Efforts to Manage Drug Expenditures and Utilization, s.l.: s.n.
Van Nuys, K., Ribero, R., Ryan, M. & Sood, N., 2021. Estimation of the Share of Net Expenditures on Insulin Captured by US Manufacturers, Wholesalers, Pharmacy Benefit Managers, Pharmacies, and Health Plans from 2014 to 2018. JAMA Health Forum, 2(11), pp. e213409–e213409. doi: 10.1001/jamahealthforum.2021.3409.35977268
Yost, D., 2018. Ohio’s Medicaid Managed Care Pharmacy Services, Auditor of State Report. [Online] Available at: https://audits.ohioauditor.gov/Reports/AuditReports/2018/Medicaid_Pharmacy_Services_2018_Franklin.pdf