# GLOSSARY

Average Manufacturer Price (AMP).: The post-concession price that manufacturers charge wholesalers.
Big Four price.: The maximum prices manufacturers may charge for direct federal purchases made by Department of Veterans Affairs, the Department of Defense, the Public Health Service, and the Coast Guard, as published in the VA’s pricing data list.
Cash price.: The price a patient pays for a drug without insurance.
Drug tenure.: Length of time the drug has been on the market.
Formulary.: A list of drugs covered by a health plan. These are often developed and maintained by PBMs.
Gross margins.: Gross margins represent earnings after subtracting payments that flow out of the intermediary from those received by that intermediary.
Manufacturer administrative fees.: The administration fee that a manufacturer pays to a PBM. This fee includes fees for collecting data and administering rebates, among other service fees.
Manufacturer DIR (direct and indirect reimbursements): is a general term describing payments from manufacturer to PBM. Includes rebates and administrative fees.
Manufacturer rebates.: Direct payments from manufacturer to PBM, often as a result of negotiations for drug formulary placement.
Margin percentage.: Gross margin divided by the net sales price.
NADAC.: The average price that a retail pharmacy pays for a drug.
National Drug Code (NDC).: 11-digit unique numeric identifier for a given drug.
Pass-through contracts.: A PBM contract structure in which the PBM passes the pharmacy reimbursement fee to the health plan.
Pharmacy DIR.: Describes retroactive fees that PBMs charge pharmacies. Pharmacy DIR is often based on pharmacy performance metrics or quality metrics determined by the PBM.
Pharmacy reimbursement fee.: The fee that a pharmacy charges PBMs for purchasing and dispensing drugs.
Spread pricing.: A PBM pricing model in which the PBM charges the third-party payer more than it reimburses the pharmacy and collects the difference.
State Drug Utilization Data (SDUD) price.: The amount that state Medicaid agencies reimburse PBMs for a drug.
Third-party payer administration fees.: Fees that PBMs charge third-party payers/health plans. These are often in the form of a fixed fee on a per-prescription basis.
Wholesale Acquisition Cost (WAC).: The manufacturer’s “list price” of a drug, i.e., the price that manufacturers charge before any price concessions.
Wholesaler discount.: Discount that wholesalers receive from the manufacturer on the WAC.