# ACKNOWLEDGEMENTS

We gratefully acknowledge Oluwarantimi Adetunji (HHS/OS/ASPE), Trinidad Beleche (HHS/OS/ASPE), Sonal Parasrampuria (HHS/CMS), and Andrea Monge (HHS/OS/ASPE) for their leadership, guidance, and input throughout this study. We also would like to thank Sharon Arnold (HHS/OS/ASPE), Laina Bush (HHS/OS/ASPE), Rebecca Haffajee (HHS/OS/ASPE), and Kathleen Miller (HHS/OS/ASPE) for their time and invaluable feedback. We are grateful to Dr. Neeraj Sood (Sol Price School of Public Policy, University of Southern California) for his thorough review of the draft report.