# EXECUTIVE SUMMARY

The U.S. supply chain for prescription drugs is highly complex, involving several intermediaries between drug manufacturers and patients. Negotiations among these supply chain intermediaries, which include pharmacy benefit managers (PBMs), pharmacies, and wholesalers, are private and the terms of their contracts are confidential. The complexity of the supply chain coupled with the lack of price transparency and opacity of interactions among supply chain intermediaries has resulted in misaligned market incentives that likely contribute to increasing prescription drug costs in the United States. Effective policies that broaden access to prescription drugs and reduce prescription drug prices while encouraging innovation must be predicated on identifying the actors and incentives that raise drug prices without increasing their value to the end user. Thus, it is important to understand where along the pharmaceutical supply chain substantial margins are generated.

In this report, we estimate the percentages of drug expenditures that are allocated to each stakeholder in the supply chain, including manufacturers. Then, we examine the gross margins (hereinafter referred to as “margins”) of three primary intermediaries in the U.S. retail^1^ prescription drug supply chain, namely wholesalers, retail pharmacies, and PBMs from Quarter 1 (Q1) 2020 to Quarter 4 (Q4) 2022.^2^

## ES.1 METHODOLOGY

We estimate margins by modeling flows of payment through the pharmaceutical supply chain on a per-prescription basis. In our stylized model, money enters the system from two major sources—claim reimbursements paid by third-party payers (i.e., public and private insurers) and copays paid by insured beneficiaries.^3^ These two financial streams make up the total drug expenditures, which flow from the PBM to the pharmacy to the wholesaler to the manufacturer. At each stage of the supply chain, a portion of these expenditures is retained to cover costs and profit, and the rest is passed along (Congressional Budget Office, 2022; Miller, et al., 2019).

We incorporate additional payment flows within the supply chain based on the strategies intermediaries use to compete for market share and maximize their profits. For example, drug manufacturers compete for formulary coverage by negotiating confidential rebates with PBMs, which results in manufacturers having a “net” price that is less than the invoice price at the time of sale (Centers for Medicare & Medicaid Services, 2017). We account for off-invoice rebates and discounts and apply these to the computed sales and acquisition costs to capture the “net” transaction values. This includes not only rebates but also direct and indirect remuneration (DIR) that the PBMs recoup from pharmacies.^4^

Of the 24,395 unique retail drugs that we identified as being in scope for this study, we determined that 7,128 met the inclusion criteria.^5^ Of those, we analyzed 3,270 for which we had complete data and price estimates at each stage of the supply chain.

For this sample of 3,270 prescription drugs sold primarily through retail outlets, this study estimates net acquisition costs and net sales prices using a variety of public data sources, including National Average Drug Acquisition Cost (NADAC), State Drug Utilization Data (SDUD), Federal Supply Service Schedule Pharmaceutical Pricing (FSS), and the Affordable Care Act Federal Upper Limit (FUL), as well as several proprietary datasets, including IQVIA National Sales Perspective (NSP), IQVIA PayerTrak, and SSR Health. In addition to the data sources above, we also relied on several published studies and reports including PBM Annual Reports published by the Iowa Insurance Division (Iowa Insurance Division, 2020-2023) and a 2019 Government Accountability Office (GAO) report on the use of PBMs and efforts to manage drug expenditures and utilization (United States Government Accountability Office, 2019).

## ES.2 KEY FINDINGS

Our results suggest that PBMs’ margins steadily increased from 23 percent in 2020 to 31 percent in 2022, while wholesalers’ margins were roughly constant at 5 to 6 percent and pharmacies’ margins decreased from 7 to 3 percent. Several factors may have contributed to the increase in PBMs’ margins, including PBM market structure and rising DIR fees paid by pharmacies. In our model, margins are sensitive to pharmacy DIR, which we estimate increased by $9.5 billion or 46.8 percent from 2020 to 2022. During this time, we estimate that pharmacies’ total margins on retail drugs decreased by $10.9 billion, or 47.2 percent.^6^ We find that, during our study period, PBMs received higher margins than pharmacies or wholesalers on nearly all types of retail drugs—brands, generics, biologics, small molecules, drugs for the treatment of acute conditions, drugs for the treatment of chronic conditions, drugs with long market tenure, and drugs with short market tenure.

Compared to generic drugs, brand drugs yielded higher margins for PBMs and wholesalers but lower margins for pharmacies, in dollar terms. For all three intermediaries, generic drugs had higher margin percentages than brand drugs. In 2022, margin percentages on generic drugs were 40.2 percent for wholesalers, 35.6 percent for pharmacies, and 53.6 percent for PBMs (see Figure ES- 1). Generic drugs also had roughly four times the utilization of brand drugs. Nonetheless, despite generics having higher volume sales and yielding higher margin percentages, PBMs and wholesalers still earned more margin dollars from brand drugs than they did from generic drugs, because brand drugs are far more expensive.

Figure ES- 1 Margin Percentage and Total Dollars by Intermediary, 2020-2022 ^[a]^ [a] Figure presents weighted population estimates. Margin percentage is calculated as weighted total margin across all drugs divided by weighted total net sales.

[b] Pharmacies are estimated to have margins of −0.2% (−$0.5 billion) on brand drugs in 2022, which corresponds to a loss. The 95% confidence interval for this value, however, extends into the positive range. See Section 4.3.1.

Figure ES-1 is a series of column charts showing the margin percentage and total margin earned by drug intermediaries from 2020 to 2022 for all drugs, branded drugs, and generic drugs. The charts show that pharmacy benefit managers receive higher margins than wholesalers and pharmacies. The charts also show that while intermediaries receive a significantly higher margin percentages for generic drugs compared to brand drugs, pharmacy benefit managers and wholesalers earn more margin dollars from brand drugs than generic drugs because brand drugs are far more expensive.

## ES.3 LIMITATIONS

This study used multiple data sources to generate estimates at the level of individual drugs where possible. However, in some cases, drug-specific estimates were not available, and so we applied a single parameter estimate to all drugs in a given group. This approach may not fully capture likely heterogeneities across different drugs.

We do not estimate several price concessions manufacturer may make, including through copay assistance programs, 340B-related discounts, the best price provision of the Medicaid rebate, administrative fees and service fees paid to the PBM, and others. Not accounting for these concessions may lead to overestimating the manufacturer rebates paid to the PBM. This would lead to underestimated pharmacy margins and overestimated PBM margins, since our calculation of pharmacy DIR is based on the estimated value of the rebate.

The NADAC survey, while providing a comprehensive source of pharmacy acquisition costs, may tend to overrepresent smaller community pharmacies. Large chain pharmacies may be able to use their market position to negotiate better prices with wholesalers, which would result in higher margins to pharmacies than we have estimated.

Our study used Medicaid reimbursements calculated from prices in the SDUD database published by the Centers for Medicare & Medicaid Services (CMS), which we have treated as representative of the pre-rebate reimbursements PBMs receive from Medicare Part D and commercial healthcare plans. However, given the recent attention and legislative efforts targeting Medicaid drug spending, the SDUD prices may be downwardly impacted by pressure within Medicaid to maintain lower third-party reimbursements. To the extent that Medicare Part D or commercial plans pay higher prices for drugs, PBM margins may be higher than we estimated.

In some cases (e.g., particularly when analyzing biologics), the sample size was relatively small. Similarly, we analyzed a three-year period that included the COVID-19 pandemic. To the extent that the pandemic had temporary impacts on retail drug prices, these effects impact our findings.

## ES.4 CONCLUSIONS

The results of this study provide insight into the distribution of drug expenditures across the members of the retail pharmaceutical supply chain. Estimates of intermediaries’ margin percentages and retained shares of net expenditures could help inform policy discussions on lowering overall prescription drug spending in the United States.

1 For the purposes of this analysis, the retail prescription channel includes prescription drugs sold through independent pharmacies, chain stores, and food stores. Mail pharmacy sales are excluded.

2 Margins represent the portion of revenue from pharmaceutical sales retained after accounting for acquisition costs. Manufacturers were excluded from the investigation of margins because this study did not quantify the costs associated with manufacturing or developing pharmaceuticals. The analysis of expenditures is intended to illustrate manufacturers’ earnings in the context of the other intermediaries without making claims about manufacturing costs.

3 The terms “beneficiary,” “patient,” and “consumer” all imply somewhat different roles, but in the context of retail prescription drug markets, all refer to the person obtaining a prescription medication from a retail outlet (i.e., independent pharmacy, chain store, or food store) for self-administration.

4 DIR comprises payments made by a pharmacy to a PBM, including (a) retrospective price concessions to “true up” the PBM’s actual reimbursements to the pharmacy with contract rates, (b) penalties assessed by the PBM based on the pharmacy’s performance metrics (e.g., generic dispense rates), and (c) network participation fees that the PBM charges to the pharmacy.

5 Specifically, drugs met the inclusion criteria if they were listed in the NADAC between 2020 and 2022 and had at least 80 percent of total sales in the retail channel according to IQVIA NSP.

6 The estimated increase in DIR fees is partly due to the model’s assumptions, as data on DIR was limited. Further research is needed on the magnitude of impact DIR has on the margins of PBMs and pharmacies. See Appendix B.5 for details on how DIR was estimated in this study and the assumptions that we used.