# 7 CONCLUSION

This study combines drug prices at the drug level from multiple sources to calculate the margins received by wholesalers, PBMs, and pharmacies in the pharmaceutical supply chain. By comparing each intermediary’s margins to their actual net sales price, we estimate that total margins for all retail drugs were 6.3 percent for wholesalers, 3.2 percent for pharmacies, and 31.2 percent for PBMs in 2022. PBM margins have been increasing at a faster pace than other intermediaries, potentially at the expense of pharmacy margins, which steadily decreased from 2020 to 2022.

Following the price of specific drugs through the supply chain, we evaluate how various drug characteristics impact the margins received by intermediaries. Supply chain intermediaries generally have higher margin percentages on generic drugs than on brand drugs but earn more margin dollars from brand drugs because of their higher prices. We observed differences in margins based on whether a drug treated acute or chronic illnesses, whether it was a biologic or small molecule drug, how long it has been in the market, and how much competition it faces in the market.

Future work can include (1) further refining our methodology for estimating pharmacy DIR payments and non-rebate forms of manufacturer DIR payments (e.g., administrative fees), both of which heavily impact PBMs’ margins; (2) examining the impact of margins on drug shortages or supply chain resilience; (3) considering the margins of unmodeled intermediaries, such as secondary wholesalers, which purchase drugs at discounted rates from primary wholesalers and then sell the product to other wholesalers or to pharmacies; and (4) modeling additional manufacturer price concessions (e.g., in the 340B program) so that manufacturer rebates can be more accurately estimated.