# 6 STUDY LIMITATIONS

This study used multiple data sources to generate estimates at the level of drug, where possible. However, in some cases, drug-specific estimates were not available, and so we applied a single parameter estimate to all drugs in a given group. For example, based on the work of Epstein et al. (2023) and the GAO study (2019), we assumed that wholesalers receive a nine percent discount off WAC for all brand drugs, which does not capture likely heterogeneities in wholesaler discounts across different brand drugs. Less expensive brand drugs with generic competition, in particular, may be more likely to have larger discounts than nine percent, which would lead to our study underestimating wholesaler margins on brands. Similarly, while the Big Four prices capture some differences in discounts, the Big Four data suggests that the wholesaler discount likely varies widely by drug. Furthermore, to the extent that Big Four prices approximate net prices, they may overestimate wholesaler discounts, which would only make up a portion of manufacturers’ total price concessions. For example, like brand drugs, generic drugs are also generally subject to statutory Medicaid rebates and discounted 340B pricing that our methodology does not account for.

The NADAC survey, while providing a very comprehensive source of pharmacy acquisition costs, has some drawbacks. The NADAC tends to overrepresent smaller community pharmacies according to one expert we interviewed for this study. Large chain pharmacies may be able to use their market position to negotiate better prices with wholesalers, which would result in higher margins to pharmacies than we have estimated—potentially on all drugs. Further, NADACs primarily capture point-of-sale discounts the wholesalers provide pharmacies; these prices do not capture all retrospective concessions such as rebates for meeting sales targets. Accounting for these price concessions may slightly reduce wholesalers’ margins and increase pharmacies’ margins.

As described in Appendix B.4 Separating Manufacturer Rebates from Other Price Concessions, we disaggregated manufacturers’ total gross-to-net discounts into only three components: rebates paid to the PBM, discounts provided to the wholesaler, and statutory rebates paid to Medicaid. A limitation is that we do not estimate other price concessions manufacturer may make, including copay assistance programs, 340B-related discounts, the best price provision of the Medicaid rebate, administrative fees and service fees paid to the PBM^38^, and others. Not accounting for these other concessions leads to higher estimates of manufacturer rebates. Our methodology thus may overestimate the portion of gross-to-net discounts that are paid to the PBM as rebate. This would lead to underestimated pharmacy margins, since our calculation of pharmacy DIR is based on the value of the rebate. Additionally, while the GAO study shows that PBMs retain rebates at 0.4 percent in Part D plans (2019), this proportion may be higher for commercial plans, which would lead to higher PBM margins than we estimated.

Our study used Medicaid reimbursements calculated from the CMS SDUD database. We have treated these SDUD prices as representative in general of the pre-rebate reimbursements PBMs receive, including from Medicare Part D and commercial healthcare plans. However, given the recent attention and legislative efforts targeting Medicaid drug spending, the SDUD prices may be influenced by greater pressure within Medicaid to maintain lower third-party reimbursements. Third-party reimbursement prices are likely higher in lines of business other than Medicaid MCOs. This may be particularly true for pharmacies, whose margins tend to be lowest in Medicaid MCOs and highest in Medicare, according to one expert interviewed for this study. Thus, the use of SDUD data may underestimate margins in general, but especially for pharmacies, and possibly also PBMs.

The CMS FUL data may tend to overestimate what the PBM pays the pharmacy. The FUL represents one of several pricing benchmarks that Medicaid agencies use to calculate drug reimbursements. In some cases, the reimbursement is based on state-published Maximum Allowable Costs (MACs), which can be lower that the FUL (Dolan & Tian, 2020). On the other hand, the FUL only provides a benchmark for ingredient reimbursement, which would be supplemented by a dispensing fee paid to the pharmacy.

Another limitation of our study is that we did not estimate manufacturers’ margins. While the analysis of each intermediary’s share of expenditures provides some insight into manufacturer earnings, the comparison of manufacturers to other intermediaries is incomplete because we have not accounted for manufacturers’ costs—in part because of a lack of data, but also because of difficulties in defining an acquisition cost that is comparable to that of the other intermediaries. Unlike the other intermediaries in our analysis, manufacturers do not purchase a finished drug product, and thus a determination must be made about the specific costs to include (e.g., ingredient costs, labor costs, development costs).

In some cases (e.g., particularly when analyzing biologics), the sample size was relatively small. Moreover, the sampled drugs may overrepresent less expensive generic drugs and more expensive brand drugs, which may partly be a consequence of excluding drugs with higher medical benefit utilization. We compared the 30,990 observations in the sample with 32,806 observations of drugs over time that were not included in the sample because pricing data was not available for every supply chain intermediary. We found that:

▪ The mean SDUD price was 64 percent lower for sampled generic drugs than unsampled generic drugs, and 33 percent higher for sampled brand drugs than unsampled brand drugs.
▪ The mean WAC was 44 percent lower for sampled generic drugs than unsampled generic drugs, and 39 percent higher for sampled brand drugs than unsampled brand drugs.
▪ The mean NADAC was 76 percent lower for sampled generic drugs than unsampled generic drugs, and 32 percent higher for sampled brand drugs than unsampled brand drugs.

Finally, there may be additional unquantified uncertainty due to data limitations; to the extent that there is a lack of pricing transparency, the data we have relied on for this study may contain other unquantified biases. Further, margins may be driven by factors that the analysis did not account for, including drug shortage status, Herfindahl-Hirschman index (a measure of market concentration), and the manufacturer’s size and location.

Nonetheless, the sample still leads to national estimates of drug utilization and spending on brands versus generics that are similar to those found in previous research. For example, using the extended unit-based weights to scale up from the sample to the population, we estimate that brand drugs made up 25.0 percent of retail drug utilization and 72.0 percent of retail drug expenditures in the United States in 2022. These are similar to the estimates for 2021 (of 20 percent and 80 percent, respectively) published by Parasrampuria & Murphy (2022).

38 Properly incorporating administrative fees paid by the manufacturer is especially important because these fees have increased recently, likely in response to the increased scrutiny of PBMs’ handling of manufacturer rebates. For example, some PBMs have established group purchasing organizations (GPOs) that charge manufacturers service fees, administrative fees, data fees, etc. (Fein, 2022).