# 5 DISCUSSION

Our study builds on the stylized model of Van Nuys et al. (2021) by accounting for certain payments (e.g., including pharmacy DIR) that occur after the point of sale and by expanding the sample of drugs, thereby providing further insight into the flow and distribution of money through the retail pharmaceutical supply chain in the United States. Using data at the drug level, we estimate the magnitude of off-invoice rebates and discounts as well as the DIR payments that PBMs recoup from pharmacies, thereby capturing net sales and acquisition costs among the retail supply chain intermediaries. Our overarching findings, discussed in depth below, are broadly in line with those of Sood, et al. (2017) and Van Nuys, et al. (2021).

Our results suggest that PBMs’ margins have steadily increased from 2020 through 2022, outpacing wholesalers and pharmacies, across all types of drugs. We find that, during the study period, PBMs received higher margins than pharmacies or wholesalers on nearly all types of retail drugs—brands, generics, biologics, small molecules, drugs for the treatment of acute conditions, drugs for the treatment of chronic conditions, drugs with long market tenure, and drugs with short market tenure. Moreover, PBMs have increased their margins on retail drug sales by $18.5 billion from 2020 to 2022. This increase has been in spite of recent legislative efforts by states requiring PBMs to pass through 100 percent of manufacturer rebates to the payer (see Appendix A: Compendium of State Statutes Addressing PBM Issues). Several factors may have contributed to this increase, including PBM market structure and rising DIR fees paid by pharmacies. First, the market in which PBMs operate is highly concentrated, with three companies controlling 79 percent of the U.S. healthcare market in 2022 (Fein, 2023). This oligopolistic market structure coupled with the critical role PBMs play in formulary management may have allowed PBMs to extract higher margins by negotiating larger rebates from drug manufacturers and increasing the DIR fees levied on pharmacies. Moreover, the vertical integration among PBMs, insurers, specialty pharmacies, and providers also strengthens PBMs’ ability to extract favorable contract arrangements from other supply chain intermediaries.^36^ Second, the high degree of consolidation of PBMs across the entire U.S. health insurance market increases their ability to create flexible reimbursement structures with pharmacies, which may allow them to comply with efforts to curb spread pricing while recouping profits in other markets. For example, PBMs’ contracts with pharmacies may specify overall average reimbursement rates across all contracts and all health insurance markets (Medicare, Medicaid, and commercial), which may allow PBMs to more than offset the lower profits they make under Part D plans with higher gains realized from commercial plans. Third, according to our analysis of public disclosures by PBMs in Iowa (Iowa Insurance Division, 2020-2023), PBMs retain 12.4 percent of total DIR. Based on our model assumptions, DIR rose over the study period, which contributed to our estimates of increasing PBM margins.^37^

As PBM margins have risen, pharmacies’ margins have decreased. In 2020, we estimate that pharmacies’ total margin on retail drugs was $23.1 billion. By 2022, this had dropped to $12.2 billion—a decrease of $10.9 billion, or 47.2 percent. In our model, this is driven largely by DIR that PBMs assess to pharmacies, which increased since we calculated pharmacy DIR in part from manufacturer rebates, which also rose during the study period. In particular, we estimate that pharmacy DIR rose from $20.3 billion in 2020 to $29.8 billion in 2022—an increase of $9.5 billion or 46.8 percent. The rising DIR therefore makes up a vast majority of the $10.9 billion loss of margins that pharmacies experienced from 2020 to 2022. This estimated increase in DIR is relatively consistent with previous DIR growth reported by CMS (see Figure 9).

Brand drugs yield higher margins for PBMs and wholesalers but lower margins for pharmacies in dollar terms compared to generic drugs. For all three intermediaries, generic drugs had higher margin percentages: 40.2 percent for wholesalers, 35.6 percent for pharmacies, and 53.6 percent for PBMs in 2022. Generic drugs also had roughly four times the utilization of brand drugs in 2022. Nonetheless, PBMs and wholesalers each earned more margin dollars from brand drugs than they did from generic drugs, because brand drugs are far more expensive. Manufacturers, in particular, benefited from the sale of brand drugs, capturing nearly three-quarters of drug spending on brands by payers and beneficiary copays in 2022. Given that brand drugs account for roughly 80 percent of all drug spending, this is a major driver of overall spending and costs to patients.

Determining the margin percentages earned by intermediaries in the retail pharmaceutical supply chain and evaluating how these margins change by entity and by drug type provides valuable information on which factors might contribute to high prices of drugs sold through retail pharmacies. These estimates could help inform policy discussions on lowering overall prescription drug spending in the United States.

36 For example, during 2022, there were several mergers between health insurance providers and PBMs that operate specialty pharmacies. These included the purchase of Aetna by CVS Health, the acquisition of Express Scripts by Cigna, the establishment of IngenioRx by Anthem, and the complex alliances formed between Express Scripts and Prime Therapeutics (Fein, 2022).

37 The estimated increase in DIR fees is partly due to the model’s assumptions, as data on DIR was limited. Further research is needed on the magnitude of impact DIR has on the margins of PBMs and pharmacies. See Appendix B.5 for details on how DIR was estimated in this study and the assumptions that we used.