# 4 RESULTS

This section presents the final sample that was selected for analysis, as well as our key findings on drugs sold through retail pharmacies. Unless noted otherwise, the following analysis presents weighted population-level estimates for calendar year 2022. For the trend analyses on brand and generic drugs, we present estimates for the full time series from 2020 to 2022.

## 4.1 Sample of Drugs Sold Through Retail Pharmacies

### 4.1.1 Drugs Selected for Sample

The right half of Figure 3 presents the number of distinct retail drugs (i.e., the count of 11-digit NDCs) in the target population, the study population, and the final sample. The target population was identified as 24,395 retail drugs listed in NADAC with verified retail sales in IQVIA NSP (excluding mail-order pharmacy sales). The study population is the subset of the target population meeting the inclusion criterion of having at least 80 percent sales in retail channels, of which there are 7,128. While this study does aim to characterize the margins of drugs with fewer than 80 percent sales in retail channels, such drugs were not considered for the sample because their reimbursements in SDUD may not be representative of retail prices, since SDUD may also include drug payments to hospital, outpatient clinics, or physician offices if billed separately from the provided healthcare services. Of the 7,128 retail drugs with at least 80 percent sales in retail channels, the final sample included 3,720 drugs for which pricing and reimbursement data were available at every level of the supply chain (including, for brand drugs, information on gross-to-net discounts).

The left half of Figure 3 shows the number of drugs that were retained at each step of merging the datasets. The final two steps do not represent dataset merging but rather the reduction in drug count when (a) applying the inclusion criterion and (b) identifying the sample with valid pricing and reimbursement information at every stage of the supply chain.

Figure 3 Selection of Sample of Retail Drugs (11-digit NDCs), 2020-2022

Note: values in parentheses are percentage that are brands/generics

[a] Only includes those for which (a) pricing and reimbursement data were available at every level of the supply chain for both brand and generic drugs, and (b) gross-to-net discount data were available for brand drugs.

Figure 3 shows the systematic process that was used in the selection of the sample o f retail drugs from 2020 to 2022. From a starting population of 29,469 NADAC drugs, the set of NADAC drugs was combined with the NSP, SDUD, SSR Health, and FUL datasets, which reduced the pool of drugs to 18,996. From there, the study population was narrowed to 7,128 drugs by limiting the scope to drugs with at least 80 percent sales in retail. Finally, the sample was narrowed to drugs with complete pricing data. The final sample included 355 brand drugs and 3,365 generic drugs, for a total of 3,720 drugs.

Prior to merging, sources that reported data more frequently than the quarter were aggregated to the level of quarter. (See Appendix B.1.) Additionally, because SDUD data is not always reported per unit, we performed a manual review of outlying values to assess whether the reimbursements were expressed on a per-package or per-unit basis. We checked for related inconsistencies, such as a WAC expressed per unit rather than per package or a NADAC expressed per package despite having a listed unit of “eaches.” In almost all such cases, external verification was possible by comparing the reported price and pack information to wholesalers’ websites, and a correction was made to convert the prices to the same units throughout all datasets. In a very small number of cases (n=8), manual exclusions were made because a product’s unit appeared to be inconsistent across datasets, and the prices could not be clearly identified as per-package or per-unit.^30^

### 4.1.2 Comparing Sample to Target Population

In general, the target population of drugs is well represented by the final sample. Table 8 compares the distribution of the sample and the target population on a variety of drug characteristics. Both the sample and the full population have approximately the same proportion of brands to generics, small molecules to biologics, and drugs treating chronic conditions to drugs treating acute conditions. The distribution of anatomical therapeutic chemicals (as identified in IQVIA NSP) is also similar between the target population and the sample. This suggests that there are not large imbalances between the sample and population in the types of drugs.

Table 8 Comparison of Study Sample to Target Population by Drug Characteristic

| Target Population | Sample
Type of Drug
Generic | 92% (n=22,328) | 90% (n=3,365)
Brand | 8% (n=2,067) | 10% (n=355)
Type of Compound
Small Molecule | 99% (n=24,246) | 99% (n=3,689)
Biologic | 1% (n=149) | 1% (n=31)
Treats Acute vs. Chronic Condition
Chronic | 69% (n=16,809) | 72% (n=2,672)
Acute | 31% (n=7,586) | 28% (n=1,048)
Anatomical Therapeutic Chemical
Nervous System | 33% (n=8,056) | 38% (n=1,406)
Cardiovascular System | 20% (n=4,916) | 21% (n=764)
Alimentary Tract and Metabolism | 10% (n=2,423) | 9% (n=340)
Anti-infectives for Systemic Use | 7% (n=1,657) | 5% (n=191)
Dermatologicals | 7% (n=1,611) | 7% (n=245)
Genito Urinary System and Sex Hormones | 6% (n=1,519) | 3% (n=123)
Musculo-skeletal System | 5% (n=1,116) | 7% (n=270)
Systemic Hormonal Preparations | 3% (n=743) | 3% (n=114)
Respiratory System | 3% (n=730) | 3% (n=97)
Sensory Organs | 2% (n=496) | 1% (n=49)
Antineoplastic and Immunomodulating Agents | 2% (n=468) | 1% (n=45)
Blood and Blood Forming Organs | 2% (n=453) | 1% (n=55)
Various | <1% (n=111) | <1% (n=11)
Antiparasitic Products, Insecticides and Repellents | <1% (n=84) | <1% (n=10)
Hospital Solutions | <1% (n=11) | 0% (n=0)
Diagnostics | <1% (n=1) | 0% (n=0)

### 4.1.3 Detailed Sample Characteristics

Table 9 shows the number of observations and distinct drugs for each year in the study period, by drug characteristic.^31^ Figure 3 shows the total number of drugs selected for the sample. Across all years, our final sample contained 3,720 distinct drugs with pricing data for all supply chain intermediaries. Of this sample, 355 were brand drugs and 3,365 were generic drugs. A drug was considered to have a “long” tenure if it had been on the market for more than 9 years if a small molecule, and more than 13 years if a biologic. Both long-tenure and short-tenure drugs are well represented in the sample (1,451 and 2,566 drugs, respectively). Drugs treating chronic conditions (n=2,672) outnumber drugs treating acute conditions (n=1,048) in the sample. There are 31 biologics in the sample, though none are 351(k) biosimilars, and roughly half (n=13) are insulin products.

Table 9 Sample Characteristics

Drug Characteristic | Total Number of Quarterly Observations of Drugs (Total Number of Unique Drugs) ^[a]^
Drug Characteristic | 2020 | 2021 | 2022 | 2020-2022
Generic | 7,897 (2,390) | 9,390 (2,754) | 10,773 (3,103) | 28,060 (3,365)
Brand | 1,054 (313) | 951 (271) | 925 (251) | 2,930 (355)
Long Tenure ^[b]^ ^[c]^ | 3,495 (1,060) | 4,026 (1,179) | 4,627 (1,311) | 12,148 (1,451)
Short Tenure | 5,456 (1,732) | 6,315 (1,930) | 7,071 (2,115) | 18,842 (2,566)
Biologic | 103 (27) | 104 (28) | 107 (27) | 314 (31)
Small Molecule | 8,848 (2,676) | 10,237 (2,997) | 11,591 (3,327) | 30,676 (3,689)
Acute Condition | 2,579 (754) | 2,811 (850) | 3,171 (940) | 8,561 (1,048)
Chronic Condition | 6,372 (1,949) | 7,530 (2,175) | 8,527 (2,414) | 22,429 (2,672)
Total | 8,951 (2,703) | 10,341 (3,025) | 11,698 (3,354) | 30,990 (3,720)

[a] The listed value is the number of unique quarterly observations of drugs. The value in parentheses is the number of unique drugs. For example, on average in 2020, there were 7,897/2,390 = 3.3 observations per drug, indicating that most generic drugs had a complete time series and were observed in all four quarters of 2020.

[b] Long” tenure refers to having more than 13 years or more than 9 years on the market for biologics and small molecules, respectively.

[c] The sum of long-tenure drugs and short-tenure drugs is greater than the number of drugs in the sample because some drugs’ status changed during the study period.

## 4.2 Descriptive Analysis

### 4.2.1 Share of Expenditures by Intermediary and Drug Type

Figure 4 presents the share of total expenditures retained by each intermediary in 2022. The corresponding dollar amounts are shown in Appendix C.2. Manufacturers retained the majority of expenditures (73.6 percent) on brand drugs in 2022, whereas supply chain intermediaries retained the majority of expenditures (78.9 percent) on generic drugs. This is consistent with supply chain dynamics. Brand drug manufacturers have more market power and serve as price setters rather than price takers given their position as exclusive suppliers of their drugs. In contrast, intermediaries have more power to negotiate lower prices for generic drugs because often there is more than one supplier for a given generic drug. While the degree of consolidation is high for all three intermediaries, PBMs appeared to be most successful at leveraging their market power for greater margins. We estimate that PBMs retained 18.3 percent of total expenditures on brands in 2022, compared to 8.1 percent retained by wholesalers and pharmacies combined. In 2022, PBMs retained an estimated 45.5 percent of expenditures on generics, compared to 33.5 percent retained by wholesalers and pharmacies combined.

The share of expenditures that manufacturers retained on brand drugs varies by several characteristics. In 2022, manufacturers received 53.0 percent of total expenditures on all drugs with a long tenure, compared to 63.2 percent of total expenditures on all drugs with a short tenure. This is likely a consequence of shorter-tenure drugs tending to be in periods of market exclusivity, whereas longer-tenure drugs tend to have more competition, which reduces manufacturers’ market power. Manufacturers received a greater share of expenditures on biologic drugs (67.0 percent) than on small molecule drugs (57.1 percent) in 2022. However, because biologics are far more likely to be dispensed in healthcare settings than by retail pharmacies, this finding may not be representative of biologics in general.

Pharmacies saw substantial discrepancies in retained expenditures across drug characteristics in 2022 according to our estimates. Pharmacies retained −0.3 percent of expenditures on brand drugs. While this represents a loss, the 95 percent confidence interval extends into the position range (see Section 4.3.1.). By comparison, pharmacies retained 19.4 percent of expenditures on generic drugs. Similarly, pharmacies retained far more of the expenditures on acute drugs (12.6 percent) than they did of chronic drug expenditures (2.4 percent). Pharmacies are also estimated to have losses on short-tenure drugs, of which they retained −2.2 percent of expenditures, but gains on long-tenure drugs, of which they retained 5.8 percent of expenditures.

Figure 5 presents trends in retained expenditures from 2020 through 2022. Based on our model, PBMs have captured an increasing share of total expenditures, both on generic drugs and brand drugs. Manufacturers’ share of expenditures has been roughly constant for brands but decreasing for generics. Pharmacies, on the other hand, have retained a roughly constant share of generic drug expenditures, but a decreasing share of brand drug expenditures. Wholesalers saw an increase in their share of brand drug expenditures in 2022 but otherwise were roughly constant over the study period, both on brands and generics.

Figure 4 Retained Share of Expenditures, by Intermediary and Drug Type, 2022 ^[a]^ [a] Figure presents weighted population estimates. Values may not sum to 100% due to rounding.

[b] Bar is too small to show; pharmacies are estimated to have retained −0.3% of total brand drug expenditures in 2022. While this is a loss, the 95% confidence interval extends into the positive range. See Section 4.3.1.

[c] “Long” tenure refers to having more than 13 years or more than 9 years on the market for biologics and small molecules, respectively.

Figure 4 is a series of column charts showing the retained share of expenditures by intermediary and drug type for 2022. The charts show that manufacturers retain the majority of expenditures (73.6 percent) on brand drugs, whereas supply chain intermediaries retain the majority of expenditures (78.9 percent) on generic drugs. The charts also show that manufacturers retain a higher percentage of expenditures for chronic drugs than for acute drugs, retain a higher percentage of expenditures for biologics than for small molecules, and retain a higher percentage of expenditures for short tenure drugs than for long tenure drugs. For the supply chain intermediaries, pharmacy benefit managers retained the highest share of expenditures, but typically less than the manufacturers, with the exception of generic drugs.

Figure 5 Retained Share of Expenditures, by Intermediary, 2020-2022 ^[a]^ [a] Figure presents weighted population estimates. Values may not sum to 100% due to rounding.

[b] Pharmacies are estimated to have retained −0.3% of total brand drug expenditures in 2022, which corresponds to a loss. The 95% confidence interval for this value, however, extends into the positive range. See Section 4.3.1.

Figure 5 is a series of column charts showing the retained share of expenditures, by intermediary, for the years 2020 through 2022. The charts show that the retained share of expenditures across intermediaries was relatively similar for 2020 and 2021. However, in 2022 the retained share for pharmacy benefit managers for all drugs increased from 20.7 percent in 2021 to 25.9 percent in 2022, the retained share for wholesalers increased from 7.9 percent to 10.0 percent, the retained share for pharmacies decreased from 7.6 percent to 5.2 percent, and the retained share for manufacturers decreased from 63.9 percent to 58.9 percent.

### 4.2.2 Margins by Intermediary

In this section, we present estimated margins on drugs sold through retail pharmacies for wholesalers, pharmacies, and PBMs. Margins are calculated in several forms, including dollars per package, total dollars across all drug sales, and aggregate percentage terms across all drug sales.

Table 10 displays margins in 2022 for wholesalers, pharmacies, and PBMs. Table 11 shows margin percentages from 2020 through 2022, including both the sample statistics and the population estimates.

Table 10 Aggregate Margins for Brand and Generic Drugs Sold Through the Retail Channel by Intermediary, 2022

Type of Drug | Intermediary | Sample Size (n) ^[a]^ | Median Net Sales Price per Package in Sample | Margin per Package ^[b]^ | Total Margin (Billions) ^[b]^ | Margin Percentage ^[b]^ ^[c]^
Brand | Wholesaler | 251 | $655.1 | $24.3 ($14.6, $32.2) | $14.1 ($8.5, $19.5) | 4.1% (2.5%, 5.3%)
Brand | Pharmacy | 251 | $641.7 | −$0.9 (−$15.1, $12.0) | −$0.5 (−$9.0, $7.1) | −0.2% (−2.5%, 2.1%)
Brand | PBM | 251 | $322.1 | $52.6 ($50.1, $55.2) | $30.7 ($26.1, $35.4) | 22.2% (20.6%, 23.9%)
Generic | Wholesaler | 3,103 | $18.3 | $5.3 ($5.0, $5.6) | $9.3 ($8.8, $9.7) | 40.2% (38.6%, 41.5%)
Generic | Pharmacy | 3,103 | $25.1 | $7.3 ($7.1, $7.5) | $12.7 ($12.0, $13.5) | 35.6% (34.5%, 36.6%)
Generic | PBM | 3,103 | $41.1 | $17.1 ($16.4, $17.9) | $29.9 ($28.6, $31.4) | 53.6% (52.7%, 54.6%)
All drugs | Wholesaler | 3,354 | $20.8 | $10.0 ($7.6, $12.3) | $23.4 ($17.7, $28.7) | 6.3% (4.8%, 7.5%)
All drugs | Pharmacy | 3,354 | $28.4 | $5.2 ($1.6, $8.5) | $12.2 ($3.6, $20.0) | 3.2% (0.9%, 5.3%)
All drugs | PBM | 3,354 | $45.7 | $26.0 ($24.6, $27.4) | $60.6 ($55.6, $65.5) | 31.2% (29.8%, 32.8%)

[a] Number of unique drugs (i.e., 11-digit NDCs) in the sample.

[b] Weighted population estimates are shown. Values in parentheses are 95% confidence intervals (see Table 13).

[c] Margin percentage is calculated as weighted total margin across all drugs divided by weighted total net sales.

Table 11 Aggregate Margin Percentage in Sample and Population, by Intermediary, Year, and Type of Drug ^[a]^

Type of Drug | Intermediary | Margin Percentage in Sample ^[b]^ | | | Margin Percentage, Population Estimate ^[b]^
Type of Drug | Intermediary | 2020 | 2021 | 2022 | 2020 | 2021 | 2022
Brand | Wholesaler | 4.5% | 4.2% | 4.7% | 3.0% | 3.0% | 4.1%
Brand | Pharmacy | 3.2% | 1.3% | −0.8% | 4.1% | 2.3% | −0.2%
Brand | PBM | 15.3% | 16.6% | 21.9% | 15.7% | 16.8% | 22.2%
Brand | Sample Size ^[c]^ | 313 | 271 | 251 | N/A | N/A | N/A
Generic | Wholesaler | 34.2% | 38.8% | 39.4% | 34.6% | 39.3% | 40.2%
Generic | Pharmacy | 33.5% | 32.3% | 36.6% | 32.8% | 31.4% | 35.6%
Generic | PBM | 44.8% | 48.7% | 54.2% | 43.7% | 48.0% | 53.6%
Generic | Sample Size | 2,390 | 2,754 | 3,103 | N/A | N/A | N/A
Total | Wholesaler | 7.0% | 6.9% | 6.8% | 5.6% | 5.4% | 6.3%
Total | Pharmacy | 6.7% | 4.6% | 2.8% | 7.3% | 5.0% | 3.2%
Total | PBM | 23.5% | 25.5% | 31.3% | 23.1% | 24.5% | 31.2%
Total | Sample Size | 2,703 | 3,025 | 3,354 | N/A | N/A | N/A

[a] Table presents weighted population estimates.

[b] Margin percentage is calculated as total weighted margin across all drugs divided by total weighted net sales.

[c] Number of unique drugs (i.e., 11-digit NDC) in the sample. Sample size is not applicable for the full population.

PBMs had the greatest total margins in total dollars and the highest margin percentages among the intermediaries in 2022. PBM margins were $60.6 billion (31.2 percent), wholesaler margins were $23.4 billion (6.3 percent), and pharmacy margins were $12.2 billion (3.2 percent). As with total expenditures, PBMs were more effective than the other intermediaries at using their market power to secure higher margins, both in dollar and percentage terms. This advantage of PBMs over the other intermediaries was estimated both for brand and generic drugs.

Across each of the three intermediaries, generic drugs generated greater margins as a percentage of the net sales price but lower margins by dollar value—with the sole exception of pharmacies, which generated more margin dollars on generics than brands. Dollar margins from generics are generally lower because they are far less expensive than brand drugs. Table 10 shows that, in 2022, compared to generics in the sample, brands had a median net sales price that was 7.8 times higher for PBM sales, 25.6 times higher for pharmacy sales, and 35.8 times higher for wholesaler sales.

Figure 6 presents margins on an annual basis for brand drugs, generic drugs, and all drugs, by intermediary. The top panel shows percent margins, and the bottom panel shows total dollar margins.

Figure 6 Margins by Intermediary, 2020-2022 ^[a]^ [a] Figure presents weighted population estimates. Margin percentage is calculated as weighted total margin across all drugs divided by weighted total net sales.

[b] Pharmacies are estimated to have margins of −0.2% (−$0.5 billion) on brand drugs in 2022, which corresponds to a loss. The 95% confidence interval for this value, however, extends into the positive range. See Section 4.3.1.

Figure 6 is a series of column charts showing the margin percentage and total margin earned by drug intermediaries from 2020 to 2022 for all drugs, branded drugs, and generic drugs. The charts show that pharmacy benefit managers receive higher margins than wholesalers and pharmacies. The charts also show that while intermediaries receive a significantly higher margin percentages for generic drugs compared to brand drugs, pharmacy benefit managers and wholesalers earn more margin dollars from brand drugs than generic drugs because brand drugs are far more expensive.

Some trends and patterns are noticeable in Figure 6. PBM margins steadily rose year over year, as did wholesaler margins on generic drugs. Wholesaler margins on brand drugs rose, while their margins on generics were approximately constant. In contrast, pharmacy margins on generic drugs remained roughly the same from one year to the next, while their margins on brand drugs declined over the study period.

### 4.2.3 Margins by Intermediary and Drug Characteristic, 2022

This section compares intermediaries’ margins in 2022 by various drug characteristics, including drugs with a long versus short tenure in the market, biologics versus small molecules, and drugs treating chronic versus acute conditions. Figure 7 presents margin percentages across all drug sales by intermediary and drug characteristic for this year.

As seen in Figure 7, PBMs’ margins were 22.2 percent on brand drugs overall and 53.6 percent on generic drugs overall in 2022. Neither of these values varies substantially based on drug characteristic. Wholesalers had very small margin percentages on brand drugs, including slightly negative margins for drugs treating acute conditions, but high margin percentages on generic drugs. Wholesalers earned slightly higher margin percentages on generic drugs treating acute conditions than on those treating chronic conditions (42.5 percent versus 38.0 percent in 2022) and on generic drugs with a short tenure than on those with a long tenure (45.8 percent versus 34.5 percent).

We found pharmacy margin percentages on brand drugs were slightly negative overall in 2022 (−0.2 percent), although the 95 percent confidence interval extends into the positive range (−2.5 percent, +2.1 percent).^32^ We similarly found that pharmacies earned relatively small margins across all drug characteristics. We estimate that they earned negative margins on brand drugs treating chronic conditions (−1.2 percent in 2022), which are partially offset by small positive margins on drugs treating acute conditions (3.9 percent). On generic drugs, in contrast, pharmacies had higher margin percentages on drugs treating chronic conditions (38.4 percent in 2022) than on drugs treating acute conditions (32.3 percent). Similarly, pharmacies’ larger negative margins on brand drugs with a short tenure (−4.4 percent in 2022) were mostly offset by positive margins on drugs with a long tenure (6.8 percent).

Figure 7 Margin Percentage, by Intermediary and Drug Type, 2022^[a]^ [a] Figure presents weighted population estimates. Margin percentage is calculated as weighted total margin across all drugs divided by weighted total net sales. “Bio.” = biologic, and “Small Mol.” = small molecule.

[b] Margins not shown for biologic generic drugs because the sample contained no biosimilar drugs.

[c] “Long” tenure refers to having more than 13 years and more than 9 years on the market for biologics and small molecules, respectively.

Figure 7 is a series of column charts showing the margin percentage by intermediary and drug type for 2022. The charts show that wholesalers, pharmacies, and pharmacy benefit managers all earn significantly higher margins on generic drugs than on brand drugs. Pharmacy benefit managers earn slightly higher margins on chronic drugs, biologics, and short tenure brand drugs compared to acute drugs, small molecules, and long tenure brand drugs. Pharmacies earn higher margins on acute brand drugs, chronic generic drugs, and long tenure brand drugs compared to chronic brand drugs, acute generic drugs, and short tenure brand drugs. Wholesalers earn higher margins on chronic brand drugs, acute generic drugs, biologics, and short tenure drugs compared to acute brand drugs, chronic generic drugs, small molecules, and long tenure drugs.

### 4.2.4 Increase in DIR over Time

Based on our analysis, increasing PBM margins are, in part, a result of rising pharmacy DIR. In our model, we assume PBMs do not pass any pharmacy DIR through to the payer, and we calculate pharmacy DIR from the total DIR that PBMs collect.^33^ Figure 8 shows the increase from 2020 to 2022 in the collected pharmacy DIR, all of which we assume PBMs retain.

Figure 8 Estimated Pharmacy DIR on All Retail Drugs

Figure 8 is a column chart showing that estimated pharmacy direct and indirect renumeration on all retail drugs has increased from $20.3 billion in 2020 to $29.8 billion in 2022.

The issue of increasing DIR was the subject of a recent CMS rulemaking, which went into effect on January 1, 2024, and requires all DIR to be estimated at the point of sale so that Medicare Part D beneficiary copays are calculated from the true cost of the drug rather than an artificially inflated price (Centers for Medicare & Medicaid Services, 2022). The CMS rule estimated that total pharmacy price concessions in Medicare Part D rose by 107,400 percent from 2010 to 2020. By our estimate, retail pharmacy DIR across Medicare, Medicaid, and commercial claims rose by another 46.8 percent during the study period, from $20.3 billion in 2020 to $29.8 billion in 2022 (see Figure 8).

To validate our methods, we re-estimated pharmacy DIR across all health insurance markets using the values published in Table 2 of CMS’s final rule (Centers for Medicare & Medicaid Services, 2022), reproduced below as Table 12. Then, we compared our original DIR estimates to the re-estimates for the year 2020, and we compared the compound annual growth rate in pharmacy DIR according to our model to the compound annual growth rate according to the CMS data.

To calculate the DIR re-estimates, we (a) divided the Part D estimates published by CMS by 0.30 since Medicare Part D makes up approximately 30 percent of retail drug spending (Cubanski, et al., 2019), and then (b) multiplied by (1 − 0.39) = 0.61 because we excluded mail-order sales, which are approximately 39 percent of total retail drug sales (Parasrampuria & Murphy, 2022). These new DIR estimates are shown in Figure 9, alongside our model’s pharmacy [underlined: DIR estimates from] Figure 8. The two estimates are highly similar for 2020—$19.4 billion according to the re-estimates compared to our model’s estimate of $20.3 billion. Moreover, using the three most recent years of CMS data (2018-2020), the compound annual growth rate in pharmacy DIR is 22.6 percent. This is highly similar to our model’s estimated compound annual growth rate in pharmacy DIR of 21.2 percent over the three-year period from 2020-2022.^34^

Table 12 Reproduction of Table 2 from CMS Final Rule (2022)

Contract Year | Total Pharmacy Price Concessions | % Change
2010 | $8,869,347 | –
2011 | $8,582,354 | −3.2%
2012 | $68,086,163 | 693.3%
2013 | $228,573,206 | 235.7%
2014 | $538,421,239 | 135.6%
2015 | $1,719,179,214 | 219.3%
2016 | $2,125,460,000 | 23.6%
2017 | $4,001,741,355 | 88.3%
2018 | $6,339,517,817 | 58.4%
2019 | $8,130,024,785 | 28.2%
2020 | $9,535,197,775 | 17.3%
CAGR 2010 – 2020 ^[a]^ | 101.0%
CAGR 2018 – 2020 ^[a]^ | 22.6%

[a] “CAGR” = Compound annual growth rate, computed as [((final value)/(initial value))^1 / number of years that passed^ − 1] × 100 % .

Figure 9 Re-Estimating Pharmacy DIR using CMS Data

Note: “CAGR” = compound annual growth rate. Re-estimates are based on CMS 2022 final rule (Centers for Medicare & Medicaid Services, 2022), assuming Part D makes up 30 percent of retail drug spending and mail-order sales make up 39 percent of retail drug spending.

Figure 9 is a column chart comparing the pharmacy direct and indirect renumeration estimated from the model to an estimate based on the Centers for Medicare and Medicaid Services data. The two estimates are highly similar for 2020: $20.3 billion compared to $19.4 billion.

Based on this comparison, we may have slightly overestimated the pharmacy DIR (discussed in detail in Section 6). However, the discrepancy may also be a consequence of PBMs collecting higher DIR in non-Medicare markets where DIR reporting is not required. These limitations notwithstanding, the growth in DIR according to our study is in line with historical growth.

## 4.3 Sensitivity Analysis

### 4.3.1 Assessing Sampling Error with 95 Percent Confidence Intervals

To evaluate the sampling error, we performed a Monte Carlo simulation consisting of 1,000 bootstrapped samples. Each bootstrap sample was equal in size to the original dataset and was generated by sampling the original dataset with replacement. We computed the margins for each bootstrapped dataset and calculated a bootstrapped 95 percent confidence interval by determining the 2.5^th^ percentile and the 97.5^th^ percentile of the set of 1,000 margin values. We also calculated the mean value across the set of 1,000 margin values.

Table 13 Empirical 95% Confidence Intervals for Margin Percentage, 2022 ^[a]^

Type of Drug | Intermediary | Margin Per Package in $ (95% Conf. Interval) | Total Margin in Billion $ (95% Conf. Interval) | Margin Percentage ^[b]^ (95% Conf. Interval)
Brand | Wholesaler | $24.3 ($14.6, $32.2) | $14.2 ($8.5, $19.5) | 4.1% (2.5%, 5.3%)
Brand | Pharmacy | −$1.0 (−$15.1, $12.0) | −$0.6 (−$9.0, $7.1) | −0.2% (−2.5%, 2.1%)
Brand | PBM | $52.7 ($50.1, $55.2) | $30.8 ($26.1, $35.4) | 22.2% (20.6%, 23.9%)
Generic | Wholesaler | $5.3 ($5.0, $5.6) | $9.3 ($8.8, $9.7) | 40.2% (38.6%, 41.5%)
Generic | Pharmacy | $7.3 ($7.1, $7.5) | $12.7 ($12.0, $13.5) | 35.5% (34.5%, 36.6%)
Generic | PBM | $17.1 ($16.4, $17.9) | $29.9 ($28.6, $31.4) | 53.6% (52.7%, 54.6%)
All Drugs | Wholesaler | $10.1 ($7.6, $12.3) | $23.4 ($17.7, $28.7) | 6.3% (4.8%, 7.5%)
All Drugs | Pharmacy | $5.2 ($1.6, $8.5) | $12.1 ($3.6, $20.0) | 3.2% (0.9%, 5.3%)
All Drugs | PBM | $26.0 ($24.6, $27.4) | $60.7 ($55.6, $65.5) | 31.3% (29.8%, 32.8%)

[a] Table presents weighted population estimates. The point estimate is the mean across all 1,000 simulations.

[b] Margin percentage is calculated as weighted total margin across all drugs divided by weighted total net sales.

As Table 13 shows, the 95 percent confidence intervals are very narrow, with the margin percentages having confidence interval widths of roughly 5 percentage points at most. It is worth noting that, for pharmacies’ margins on brand drugs, the 95 percent confidence interval extends into the positive range, from −2.5% to 2.1%. The low sampling error indicates that the large sample yielded high degrees of precision. The mean values in Table 13 are highly similar to the main estimates of Table 10, suggesting that there is very little, if any, bootstrap bias.

We also calculated 95 percent confidence intervals for the share of total expenditures that each intermediary retains (see Table 14). As above, the confidence intervals are narrow, indicating that sampling error is low.

Table 14 Empirical 95% Confidence Intervals for Total Expenditures, 2022 ^[a]^

Type of Drug | Intermediary | Total Expenditure in Billion $ (95% Confidence Interval) | Perc. Retained of Total Expenditures (95% Confidence Interval)
Brand | Wholesaler | $14.2 ($8.5, $19.5) | 8.4% (5.0%, 11.1%)
Brand | Pharmacy | −$0.6 (−$9.0, $7.1) | −0.4% (−5.3%, 4.2%)
Brand | PBM | $30.8 ($26.1, $35.4) | 18.2% (17.0%, 19.3%)
Brand | Manufacturer | $124.7 ($109.1, $140.9) | 73.8% (71.1%, 76.9%)
Generic | Wholesaler | $9.3 ($8.8, $9.7) | 14.1% (13.4%, 14.7%)
Generic | Pharmacy | $12.7 ($12.0, $13.5) | 19.3% (18.7%, 20.0%)
Generic | PBM | $29.9 ($28.6, $31.4) | 45.5% (44.6%, 46.3%)
Generic | Manufacturer | $13.9 ($13.3, $14.5) | 21.1% (20.5%, 21.8%)
All Drugs | Wholesaler | $23.4 ($17.7, $28.7) | 10.0% (7.5%, 11.9%)
All Drugs | Pharmacy | $12.1 ($3.6, $20.0) | 5.2% (1.6%, 8.5%)
All Drugs | PBM | $60.7 ($55.6, $65.5) | 25.8% (24.8%, 26.9%)
All Drugs | Manufacturer | $138.6 ($123.1, $154.6) | 59.0% (56.7%, 61.5%)

[a] Table presents weighted population estimates. The point estimate is the mean across all 1,000 simulations.

### 4.3.2 Sensitivity of Results to Individual Parameters

To assess uncertainty associated with the model assumptions, we selected five parameters (listed below) and recalculated margins when decreasing or increasing only one parameter at a time. Each parameter was decreased and increased by 20 percent its original value, yielding low and high re-estimates. We adjusted the following model assumptions:

▪ For brand drugs, PBMs retain 12.4 percent of the total DIR they collect, which includes manufacturer rebates and pharmacy DIR.
▪ For generic drugs, wholesalers pay 100 percent of the Big Four price. In our main analysis, this leads to wholesalers receiving a 65.1 percent discount off the WAC, on average, among the full target population.^35^
▪ For brand drugs, wholesalers receive a uniform discount of 9 percent off the WAC.
▪ PBMs charge an average administrative fee of $2 per brand prescription.
▪ For generic drugs, PBMs assess pharmacies a total DIR fee equal to eight percent of gross profit.

We found that, in most cases, 20 percent variation in the parameter produces relatively small changes in the margin percentages (Table 15). With only a few exceptions, the aggregate margin percentages varied by less than four percentage points.

Table 15 Results of Sensitivity Analysis ^[a]^

Parameter ^[b]^ | Type of Drug | Intermediary | Aggregate Margin
Parameter ^[b]^ | Type of Drug | Intermediary | Total (Billions) | Per Package | Percentage ^[c]^
PBMs’ retained 12.4% of collected DIR on brands | Brand | Pharmacy | (−$7.5, $6.0) | (−$12.8, $10.3) | (−2.2%, 1.7%)
PBMs’ retained 12.4% of collected DIR on brands | Brand | PBM | ($24.1, $37.6) | ($41.4, $64.6) | (17.5%, 27.2%)
Wholesalers pay 100% of Big Four price for generics | Generic | Wholesaler | ($0.9, $17.6) | ($0.5, $10.1) | (3.9%, 76.4%)
Wholesalers receive 9% discount off WAC for brands | Brand | Wholesaler | ($7.5, $20.7) | ($12.9, $35.6) | (2.2%, 6.0%)
Wholesalers receive 9% discount off WAC for brands | Brand | Pharmacy | (−$1.4, $0.4) | (−$2.5, $0.6) | (−0.4%, 0.1%)
Wholesalers receive 9% discount off WAC for brands | Brand | PBM | ($29.8, $31.6) | ($51.1, $54.2) | (20.6%, 24.0%)
PBMs charge an admin fee of $2 per brand claim | Brand | Pharmacy | (−$0.8, −$0.3) | (−$1.3, −$0.5) | (−0.2%, −0.1%)
PBMs charge an admin fee of $2 per brand claim | Brand | PBM | ($30.5, $30.9) | ($52.2, $53.0) | (22.0%, 22.4%)
PBM DIR is 8% of pharmacy profit for generics | Generic | Pharmacy | ($12.5, $13.0) | ($7.2, $7.4) | (35.2%, 36.0%)
PBM DIR is 8% of pharmacy profit for generics | Generic | PBM | ($29.7, $30.1) | ($17.0, $17.2) | (53.3%, 53.9%)

[a] Weighted population estimates are presented. Intermediaries whose margins did not change in a given scenario are not shown.

[b] Each parameter was decreased and increased by 20 percent of its original assumed value.

[c] Margin percentage is calculated as total weighted margin across all drugs divided by total weighted net sales.

Among the parameters we evaluated, margins are most sensitive to changes in the assumption that wholesalers pay 100 percent of the Big Four price to acquire generics. Adjusting this to 80 percent and 120 percent caused wholesalers’ generic margins to vary from 3.9 percent to 76.4 percent, which is a very wide range in response to only 20 percent variation in the assumption. PBMs’ margins on brand drugs are sensitive to the assumption that total retained DIR is 12.4 percent of the total DIR they collect (including rebates and pharmacy DIR). A 20 percent change in this parameter (from 9.9 to 14.9 percent) caused pharmacy margins on brands to vary from −2.2 to +1.7 percent, and these parameter adjustments also caused pharmacy margins on brands to vary from 17.5 to 27.2 percent, which is a relatively large spread.

Overall, the results are not highly sensitive to the original assumptions, with the main exception of wholesalers’ margins on generic drugs. In addition, PBMs’ margins on brand drugs also have moderate model uncertainty. The other margins were largely unchanged when we adjusted the selected parameters.

30 See Appendix B.1 for more detail.

31 Appendix C.1 provides sample counts when a drug is defined as a unique manufacturer-molecule (active ingredient)-formulation combination.

32 See Table 13 for 95 percent confidence intervals. As discussed in Section 6, our methodology may overestimate the DIR that PBMs assess pharmacies because the calculation of pharmacy DIR is based on the estimate of manufacturer rebates, and we did not model all discounts manufacturers give to supply chain entities. Similarly, as shown in Section 4.3.1, the point estimate for pharmacy margins on brands increases to 1.7 percent when we assume PBMs retain 9.92 percent of DIR (i.e., 20 percent lower than the original estimate of 12.4 percent).

33 Based on our analysis of PBM Annual Reports published in Iowa (Iowa Insurance Division, 2020-2023), PBMs retain 12.4 percent of the total DIR they collect, which we estimate as the sum of manufacturer rebates and pharmacy DIR.

34 Using the CMS-based DIR estimates, the compound annual growth rate in pharmacy DIR is ($19.4B/$12.9B)^0.5^ = 22.6%. Using our estimates, the compound annual growth rate in pharmacy DIR is ($29.8B/$20.3B)^0.5^ = 21.2%.

35 Within the sample, the average wholesaler acquisition discount is 66.2 percent off WAC for generic drugs.