# 3 METHODOLOGY

This section provides an overview of our methodology and presents the data sources. For an expanded discussion of these topics, see Appendix B: Detailed Methodology.

## 3.1 Data and Definitions

Table 6 shows payments made among the intermediaries of the retail drug supply chain.

Table 6 Types of Payments in the Retail Drug Supply Chain

Payment Type | Description
Wholesale acquisition cost | Manufacturer’s list price to wholesalers or other bulk purchasers.
Wholesaler net acquisition cost | Actual price paid, net of fees and discounts, by wholesaler to manufacturer (is typically less than the listed WAC).
National average drug acquisition cost | National estimate of the net price paid by pharmacies for a drug.
State Drug Utilization Data price | The average price paid by state Medicaid agencies for a drug, averaged across all states and all plan types (including Managed Care Organizations and Fee-for-Service). Used to estimate pre-rebate reimbursement rates to PBMs by all payers.
Copay | An out-of-pocket payment made by the beneficiary to the pharmacy for a prescription drug, which represents the beneficiary’s shared portion of the cost.
Pharmacy direct and indirect remuneration | Payments made by the pharmacy to the PBM, including retrospective price concessions to “true up” the PBM’s actual reimbursements to the pharmacy with contract rates, penalties assessed by the PBM based on the pharmacy’s performance metrics (e.g., generic dispense rates), and network participation fees that the PBM charges to the pharmacy.
Manufacturer rebate | A payment made by the manufacturer to the PBM based on a drug’s utilization. Some of this rebate is retained by the PBM, and the rest is passed on to the manufacturer.
Manufacturer administrative fees | Fees paid by the manufacturer to the PBM (other than the rebate).
Third party payer administrative fees | Fees paid by third-party payers to the PBM per prescription on passthrough contracts.
Manufacturer DIR | A broad term that captures all payments from the manufacturer to the PBM, including both rebates and administrative fees.

We used the following datasets for this analysis. For all datasets, we used a period spanning the beginning of 2020 to the end of 2022; these represented the most recent data available at the time of our analysis.

▪ National Average Drug Acquisition Cost is a price database published by CMS based on the Retail Drug Survey, a national survey of all retail community pharmacies. The NADAC is the average price at which sampled pharmacies purchase a drug from manufacturers or wholesalers, including some discounts. We used the NADAC to estimate wholesalers’ net sales price, which we assume is equal to pharmacies net acquisition cost. We also used the database of NADACs to define the universe of retail drugs. This may not capture some drugs only sold through specialty pharmacies or pharmacies that dispense prescriptions primarily through the mail, for which pharmacies’ net acquisition costs are not available.
▪ IQVIA National Sales Perspective (NSP) is a nationally representative database of U.S. drug supply volume reported monthly. IQVIA NSP covers nearly the full universe of drug utilization across all channels (retail, non-retail, and mail), although we focus exclusively on the retail channel. For this analysis, we filtered IQVIA NSP to include only drugs that appear in the NADAC dataset. Then, because third-party payers may reimburse these retail drugs at different rates when dispensed in non-retail channels, we further subset the retail drugs to those with at least 80 percent sales in retail channels (excluding mail), according to IQVIA NSP. We used NSP’s reported value of the WAC, which is the manufacturer’s list price. In cases where a single NDC had multiple WACs in retail channels, we used the WAC for the original manufacturer package sold. From the WAC, we calculated wholesalers’ net acquisition cost (which is generally less than the WAC) as well as rebates PBMs collect from manufacturers.^20^ IQVIA NSP also reports total mass (in kg) or activity (in IU) sold of the active pharmaceutical ingredient (API), as well as the number of extended units sold (i.e., smallest amount of the drug). We used these extended units to compute weights and to estimate total utilization of the sampled retail drugs across all markets (Medicaid, Medicare Part D, and commercial plans). Thus, the analysis is based on a nationally representative sample of all retail sales for prescription drugs in the United States.
▪ IQVIA PayerTrak is a database of prescription drug utilization in the United States by payer type and provides monthly national projections of the number of prescriptions filled and average copay by payer. We used these data to calculate average copays across all states and payer types for each drug in our sample, weighted by projected total prescriptions (TRx).^21^ We matched PayerTrak copays to drugs in our sample using the molecule (combined molecule), product name, formulation (form TLC3), strength, brand/generic status, USC3 designation, corporation, manufacturer, and product launch date.
▪ SSR Health is a database of brand drugs’ gross (i.e., WAC) and net prices from the perspective of the drug manufacturer. SSR Health’s database contains quarterly data on rebates and other price concessions since 2007, averaged across all payers. We used the gross-to-net discount rates, which show manufacturers’ total price concessions as a fraction of the WAC by market (Medicaid, non-Medicaid, and overall). From these gross-to-net discount rates and from the estimated wholesaler discounts, we computed the estimated size of manufacturer rebates as a fraction of the WAC.
▪ State Drug Utilization Data (SDUD) is published by CMS and reports the number of units reimbursed and dollars spent on drugs by state Medicaid agencies, before adjusting for rebates paid into the Medicaid Drug Rebate Program. We used the SDUD prices (which do not account for rebates) to estimate pre-rebate reimbursements that third-party payers make to PBMs in all plans, including Medicaid, Part D Medicare, and commercial plans. In SDUD, drug sales include both the retail and non-retail channels, which cannot be disaggregated.
▪ Federal Supply Service (FSS) Schedule Pharmaceutical Pricing File is published by the U.S. Department of Veterans Affairs (VA) and provides data on maximum prices that pharmaceutical manufacturers may charge for direct federal purchases made by the Big Four federal agencies (i.e., the Department of Veterans Affairs, the Department of Defense, the Public Health Service, and the Coast Guard) (U.S. Department of Veterans Affairs, Office of Procurement, Acquisition and Logistics, 2023).^22^ A recent study used Big Four prices to estimate net prices of brand drugs (3 Axis Advisors, 2023). Since generic drugs have no PBM rebates, we used the Big Four prices to estimate wholesalers’ net acquisition costs.^23^
▪ The Affordable Care Act Federal Upper Limit (FUL) is a pricing database published monthly by CMS to establish the maximum allowable Medicaid reimbursement for multiple source drugs. The FUL is calculated as either 175 percent of reported utilization-weighted average manufacturer prices (net of rebates) of pharmaceutically equivalent products available for purchase by retail pharmacies, or the NADAC price, whichever is greater. We used FUL to estimate the reimbursement from PBMs to pharmacies for generic drugs.
▪ National Drug Code Directory is a database maintained by the U.S. Food & Drug Administration (FDA) of drugs sold in the United States, which expresses NDCs in 10-digit formats. We converted these 10-digit NDCs into 11-digit NDCs by adding a leading 0 at the appropriate location (Maryland Department of Health Center for Immunization, n.d.) and merged the NDC Directory into the CMS and IQVIA NSP datasets to assist in converting package quantity into API quantity.

As stated above, we define a drug as being a unique 11-digit NDC, and our analytic dataset tracks all pricing and sales volume information at the drug level from Q1 2020 through Q4 2022. The datasets above were used to apply the inclusion criteria. We used the IQVIA NSP dataset to identify and exclude (a) non-prescription drugs and (b) drugs with no API utilization data, since the API unit was used as a stratifying variable when calculating weights (see Section 3.4).^24^ We used the NADAC survey to identify retail drugs, which allowed us to exclude non-retail drugs from our study. Similarly, in IQVIA NSP, we excluded non-retail channels in order to quantify just the retail drug sales.^25^ Drugs only sold through specialty pharmacies and mail-order drugs are also excluded from the universe and omitted from the study because their price information is less readily available, as they do not have a NADAC and are not included in CMS’s pharmacy survey of retail drugs.

## 3.2 Theoretical Framework

In this section, we provide mathematical definitions of the monetary quantities that we estimated. In the Section 3.3, we describe how we estimated those quantities from the available data.

In general, we define the margin Y_x , i_^( t )^ for a given intermediary x on a drug i for time t as the difference between the total incoming payments for the drug during that time and the total outgoing payments. For wholesalers and pharmacies, the drug-level margin Y_x , i_^( t )^ is equal to the difference between the sales price (net of discounts and rebates) S_x , i_^( t )^ and the acquisition cost (net of discounts and rebates) A_x , i_^( t )^ .

Y_x , i_^( t )^ = S_x , i_^( t )^ − A_x , i_^( t )^ Equation 1: Y superscript open parentheses t close parentheses end superscript subscript x comma i end subscript equals S superscript open parentheses t close parentheses end superscript subscript x comma i end subscript minus A superscript open parentheses t close parentheses end superscript subscript x comma i end subscript. (1)

For wholesalers, the margin is the difference between the net sales price (which we label NADAC_i_^( t )^ ) and the net acquisition cost. We estimated wholesalers’ net acquisition cost as the WAC minus all wholesaler discounts d_whole , i_^( t )^ :^26^

Y_whole , i_^( t )^ = NADAC_i_^( t )^ − (WAC_i_^( t )^) (1 − d_whole , i_^( t )^) Equation 2: Y superscript open parentheses t close parentheses end superscript subscript whole comma i end subscript equals NADAC superscript open parentheses t close parentheses end superscript subscript i end subscript minus open parentheses WAC superscript open parentheses t close parentheses end superscript subscript i end subscript close parentheses times open parentheses 1 minus d superscript open parentheses t close parentheses end superscript subscript whole comma i end subscript close parentheses. (2)

For pharmacies, the net sales price is the beneficiary copay C_i_^( t )^ plus the net payment from the PBM A_PBM , i_^( t )^ . The net payment A_PBM , i_^( t )^ is equal to the total payment from the PBM less the pharmacy’s DIR D_pharm , i_^( t )^ .

Y_pharm , i_^( t )^ = (C_i_^( t )^ + A_PBM , i_^( t )^) − NADAC_i_^( t )^ where A_PBM , i_^( t )^ = PBM reimbursement − D_pharm , i_^( t )^ Equation 3: Y superscript open parentheses t close parentheses end superscript subscript pharm comma i end subscript equals open parentheses C superscript open parentheses t close parentheses end superscript subscript i end subscript plus A superscript open parentheses t close parentheses end superscript subscript PBM comma i end subscript close parentheses minus NADAC superscript open parentheses t close parentheses end superscript subscript i end subscript. Where A superscript open parentheses t close parentheses end superscript subscript PBM comma i end subscript equals PBM reimbursement minus D superscript open parentheses t close parentheses end superscript subscript pharm comma i end subscript. (3)

For PBMs, the margin calculation is more complicated. The payment flows into the PBM include the SDUD payment from the third-party payer, the pharmacy DIR, D_pharm , i_^( t )^ , and the manufacturer DIR, D_manf , i_^( t )^ . The PBM retains a fraction, k_pharm_, of the pharmacy DIR (which we assume to be 100 percent) and a fraction, k_manf_, of the manufacturer DIR. These fractions are not indexed by drug i or time t because we assumed they were the same for all drugs and time periods as we did not have time-specific or drug-specific estimates. The payments made by the PBM include the pharmacy reimbursement, the non-retained pharmacy DIR, and the nonretained manufacturer DIR. The margin is:

Y_PBM , i_^( t )^ = SDUD_i_^( t )^ + k_manf_ D_manf , i_^( t )^ + k_pharm_ D_pharm , i_^( t )^ − (PBM reimbursement)_i_^(t)^ Equation 4: Y superscript open parentheses t close parentheses end superscript subscript PBM comma i end subscript equals SDUD superscript open parentheses t close parentheses end superscript subscript i end subscript plus k subscript manf end subscript times D superscript open parentheses t close parentheses end superscript subscript manf comma i end subscript plus k subscript pharm end subscript times D superscript open parentheses t close parentheses end superscript subscript pharm comma i end subscript minus open parentheses PBM reimbursement close parentheses superscript open parentheses t close parentheses end superscript subscript i end subscript. (4)

In summary, we calculate wholesalers’ and pharmacies’ margins in dollars as the difference between the net sales price and the net acquisition cost. For PBMs, we calculated the dollar margin as this difference plus any retained manufacturer DIR, such as manufacturer rebates. We used net prices to account for the effects of discounts and rebates to better reflect intermediaries’ actual financial experience. For PBMs, rebates from the manufacturer constitute an additional flow that is distinct from the sale to the payer and the acquisition from the pharmacy. The effect of this additional flow is to lower the PBM’s net sales price (because a portion of the rebate is passed on to the third-party payer) and to increase the margin (because the remaining proportion is retained by the PBM). For all three parties, we define the margin percentage as the margin divided by the net sales price.

In addition to calculating margins, we also computed the total expenditures, which we define to be the total net payments made by the third-party payer and the beneficiary. We estimate the total expenditures E^(t)^ at time t, for all drugs i, as the SDUD payment and beneficiary copay less the portion of the manufacturer rebate that the PBM passes on to the payer:

E^( t )^ = ∑_i_ SDUD_i_^( t )^ + C_i_^( t )^ − k_manf_ D_manf , i_^( t )^ Equation 5: E superscript open parentheses t close parentheses end superscript equals sum from i equals 1 to n of open parentheses SDUD superscript open parentheses t close parentheses end superscript subscript i end subscript plus C superscript open parentheses t close parentheses end superscript subscript i end subscript close parentheses. (5)

In addition to estimating each intermediary’s margin percentage, we also estimated the fraction of total expenditures E^(t)^ that each intermediary retains. This fraction is calculated using the intermediary’s margin or the amount of payer/beneficiary spending that the supply chain entity retained:

fraction of total expenditures retained by intermediary x at time t = (∑_i_ Y_x , i_^( t )^)/(E^( t )^) Equation 6: fraction of total expenditures retained by intermediary x at time t equals begin fraction open parentheses sum from i equals 1 to n of Y superscript open parentheses t close parentheses end superscript subscript x comma i end subscript close parentheses over open parentheses E superscript open parentheses t close parentheses end superscript close parentheses end fraction. (6)

While we are unable to calculate the margin percentages for manufacturers, we can estimate the portion of expenditures that manufacturers receive as the total expenditures minus the margins of all other intermediaries (see equation 7). However, this may not be directly comparable to the portion of expenditures that other intermediaries retain since we have not accounted for manufacturers’ acquisition costs (which, unlike the acquisition costs of the other intermediaries, is not a price for the finished product and thus could include sourcing, production, or R&D costs, depending on definitions).

amount of total expenditures retained by manufacturer at time t = E^(t)^ − ∑_x ≠ mfr_ ∑_i_ Y_x , i_^(t)^ Equation 7: amount of total expenditures retained by manufacturer at time t equals E superscript open parentheses t close parentheses end superscript minus sum for all x that do not equal mfr of open parentheses sum from i equals 1 to n of open parentheses Y superscript open parentheses t close parentheses end superscript subscript x comma i end subscript close parentheses close parentheses. (7)

In Section 3.3, we describe how these quantities were estimated. In Section 3.4, we describe how the drug-level margins Y_x , i_^( t )^ are scaled up using utilization and weights to estimate aggregate margins M_x_, margin percentages %M_x_, and aggregate margin per package m_x_ for each intermediary when aggregating across all drugs in a given time period.

## 3.3 Modeled Payment Flows for Drugs Sold Through Retail Pharmacies

For each sampled prescription retail drug, we modeled the flows of payment through the pharmaceutical supply chain on a per-prescription basis (Figure 2). Table 7 shows the data sources and calculation methods for each payment flow. Broadly, the stylized model begins with the main financial input into the system, the reimbursement from the payer. This initial payment is passed along through the supply chain, and at each stage, the intermediary keeps a portion and uses the rest to reimburse the next stakeholder. We assume the sum of the dollar amounts retained by the intermediaries and manufacturers equals the total inputs into the system, thus forming a closed system among the entities shown in Figure 2. In addition to the payer’s reimbursement, a secondary input is the beneficiary’s copay, and together, these make up the total financial inputs. There are also upward payment flows in the diagram, which represent rebates that manufacturers pay to PBMs and pharmacy DIR. The total expenditures refer to the net spending, i.e., the total payments by the beneficiary and the payer minus the portion of the manufacturer rebate that is passed on to the payer.

### 3.3.1 Brand Drugs

The left part of Figure 2 presents our stylized model for the payment flows of a brand drug prescription. Below, we describe each of these flows through the supply chain, though not necessarily in the chronological order in which they are usually incurred or paid.

When a drug is dispensed, the third-party payer provides payment to the PBM (flow 1). The PBM may retain an administrative fee on a per-prescription basis (flow 2), and it passes the remainder to the pharmacy (flow 3) to cover ingredient costs and dispensing fees. The pharmacy also receives a copay from the beneficiary (flow 4). Pharmacies may pay one or more types of direct and indirect remuneration (DIR) fees to PBMs (flow 5), which can be assessed after the point of sale. The PBM may retain a portion of this DIR fee (flow 6) and pass the rest on to the third-party payer (flow 7), though our calculations assume that all of the pharmacy DIR is retained by the PBM. The pharmacy purchases the drug from the wholesaler at a net price that accounts for rebates and discounts (flow 8). The wholesaler purchases the drug from the manufacturer at a discounted rate off the WAC (flow 9). The manufacturer often passes some of the payment on to the PBM as a rebate and/or administrative fees (flow 10). A portion of this rebate is retained by the PBM (flow 11), and the rest is passed on to the third-party payer (flow 12).

We modeled the third-party payer reimbursement (flow 1) using the SDUD price calculated from published CMS data. When calculating the price based on the SDUD CMS data, we used both the Managed Care Organization (MCO) and Fee-for-Service (FFS) reimbursement amounts. We assumed the administrative fee (flow 2) is $2.00 per prescription when averaged across pass-through contracts (which may apply a typical fee of approximately $4.00 (RxBenefits, 2020) and traditional contracts (which would not have such a fee). In addition, our estimate of $2.00 is consistent with an average spread of 0.8 percent on brand drugs, as reported in a 2018 Ohio Auditor of State report (Yost, 2018). Based on our analysis, applying exactly 0.8 percent would have yielded an average per-prescription administrative fee of $2.45 for brand drugs in our sample.

Figure 2 Payment Flows per Prescription for a Drug Sold Through the Retail Channel

Figure 2 is a flow chart showing the payment flows per prescription for a drug sold through the retail channel for brand drugs and generic drugs. First, a third-party payer or healthcare plan pays reimbursement to a pharmacy benefit manager. The pharmacy benefit manager pockets a portion of that reimbursement for administrative fees. The pharmacy benefit manager then pays an ingredient and dispensing fee to the pharmacy, while the beneficiary also pays a copay to the pharmacy. The pharmacy pays the national average drug acquisition cost to the wholesaler, and the wholesaler pays a discounted wholesale acquisition cost to the manufacturer. Direct and indirect renumeration flows from the pharmacy to the pharmacy benefit manager, which passes on a portion of that renumeration to the third-party payer or healthcare plan. For brand drugs specifically, the manufacturer also pays a rebate to the pharmacy benefit manager, which passes on a portion of that rebate to the third-party payer or healthcare plan.

Table 7 Data Sources for Modeling Payment Flows

Payment Flow | Data Source(s) and Calculation Method
Payment Flow | Brand Drugs | Generic Drugs
(1) Third-party payer reimbursement | Estimated from CMS State Drug Utilization Data (2020-2022) | Estimated from CMS State Drug Utilization Data (2020-2022)
(2) Administrative fees | Assumed to be $2 per package sold, based on market research and a 0.8% total price spread on brands reported by the Ohio Auditor of State (Yost, 2018) | Not estimated separately because this is incorporated into the calculation of (3) for generics
(3) Ingredient + dispensing fee | (1) – (2) | Estimated as the CMS FUL price
(4) Copay | Calculated from IQVIA PayerTrak (2020-2022), or average copay of $56 if data not available (Association for Accessible Medicines, 2022) | Calculated from IQVIA PayerTrak (2020-2022), or average copay of $6 if data not available (Association for Accessible Medicines, 2022)
(5) Pharmacy DIR | Estimated as 13.7% of (10) ^[a]^ | Assumed to equal 8% of the difference between the pharmacy’s sales price and purchase price
(6) Retained pharmacy DIR | Assumed to be 100% of collected pharmacy DIR | Assumed to be 100% of collected pharmacy DIR
(7) Portion of pharmacy DIR passed on | (5) – (6) | (5) – (6)
(8) NADAC | Calculated from CMS NADAC survey (2020-2022) | Calculated from CMS NADAC survey (2020-2022)
(9) Discounted WAC | Assumed to be 9% of WAC listed in IQVIA NSP (United States Government Accountability Office, 2019) | Calculated from the WAC in IQVIA NSP (2020-2022), with a discount based on Big Four prices (2020-2022)
(10) Manufacturer rebate | Calculated from SSR Health (2020-2022) and WAC in IQVIA NSP (2020-2022) ^[b]^ | Assumed to be $0 for generic drugs
(11) Retained fraction of rebate | Assumed to be 0.4% based on report by U.S. Government Accountability Office (2019) | Assumed to be $0 for generic drugs
(12) Portion of rebate passed on to third-party payer | (10) – (11) | (10) – (11)

[a] We assumed the PBM retains 12.4% of the total collected DIR based on Iowa PBM Annual Reports (2021-2022). We modeled the total collected DIR as (manufacturer rebate) + (pharmacy DIR), and we modeled the retained amount as (0.4%)(manufacturer rebate) + (100%)(pharmacy DIR). Therefore: (12.4%)(manufacturer rebate + pharmacy DIR) = (0.4%)(manufacturer rebate) + (100%)(pharmacy DIR), which simplifies to (pharmacy DIR) = (13.7%)(manufacturer rebate). See Section 3.3.1 for more details.

[b] We have not modeled all price concessions made by the manufacturer, including, for example, 340B discounted prices and manufacturer payments made through copay assistance programs. This likely leads to an overestimate of the rebate and, consequently, pharmacy DIR.

We modeled the pharmacy reimbursement (flow 3) as the difference between the third-party payer reimbursement and the PBM’s retained fee: (flow 3) = (flow 2) – (flow 1). The copay (flow 4) is estimated from IQVIA’s PayerTrak dataset as a weighted average across all states and payers. In cases where copay information was not available in IQVIA PayerTrak or could not be matched to a specific drug, we used an average copay of $56 for brand drugs and $6 for generic drugs, based on a 2022 report (Association for Accessible Medicines, 2022).^27^

We used NADAC to model the net price between the pharmacy and wholesaler (flow 8). CMS’s Retail Price Survey only covers retail pharmacies and accounts for most rebates and discounts that the wholesaler provides to the pharmacy. We modeled the wholesaler’s net acquisition cost (flow 9) by taking 91 percent of the WAC published in IQVIA NSP, which is equivalent to one minus the 9 percent discount rate estimated by researchers at the Urban Institute (Epstein, et al., 2023) based on a Government Accountability Office (GAO) study (2019) that compared average manufacturer prices (AMPs) to WACs for top-selling drugs.

We estimated manufacturer rebates (flow 10) from SSR Health data on mean gross-to-net discounts. We accounted for statutory rebates paid to the Medicaid Drug Rebate program, which generate no revenue for the PBM and are separate from the rebates manufacturers collect. We did not estimate the administrative fees that manufacturers pay PBMs. We assumed the PBM retains 0.4 percent of the manufacturer rebates (flow 11) based on a GAO study (2019), and that the remaining 99.6% of the manufacturer rebate is passed on to the third-party payer (flow 12). Calculations of manufacturer rebates are discussed in detail in Appendix B.4.

Our estimates of total pharmacy DIR that the PBM collects (flow 5) and retains (flow 6) are based on a number of inputs and assumptions. We modeled the total DIR retained, DIR_ret_, as being made up of a retained portion p_ret, pharm DIR_ of the collected pharmacy DIR DIR_ph_ and a retained portion p_ret, mfr reb_ of the manufacturer rebate reb_mfr_:

DIR_ret_ = (p_ret, pharm DIR_) (DIR_ph_) + (p_ret, mfr reb_) (reb_mnf_) Equation 8: DIR subscript ret end subscript equals open parentheses p subscript ret comma pharm DIR end subscript close parentheses times open parentheses DIR subscript ph end subscript close parentheses plus open parentheses p subscript ret comma mfr reb end subscript close parentheses times open parentheses reb subscript mnf end subscript close parentheses. (8)

The proportion of total DIR retained, p_ret, tot DIR_, can be expressed as the ratio of total retained DIR to total collected DIR. We modeled the total collected DIR as the sum of manufacturer rebates and collected pharmacy DIR:

p_ret, tot DIR_ = (total DIR retained in $)/(total DIR collected in $) = (DIR_ret_)/(reb_mfr_ + DIR_ph_) Equation 9: p subscript ret comma tot DIR end subscript equals begin fraction open parentheses total DIR retained in $ close parentheses over open parentheses total DIR collected in $ close parentheses end fraction equals begin fraction open parentheses DIR subscript ret end subscript close parentheses over open parentheses reb subscript mfr end subscript plus DIR subscript ph end subscript close parentheses end fraction. (9)

Combining equations 8 and 9 yields the expression below:

p_ret , tot DIR_ = ((p_ret, pharm DIR_) (DIR_ph_) + (p_ret, mfr reb_) (reb_mnf_))/(reb_mfr_ + DIR_ph_) Equation 10: p subscript ret comma tot DIR end subscript equals begin fraction open parentheses open parentheses p subscript ret comma pharm DIR end subscript close parentheses times open parentheses DIR subscript ph end subscript close parentheses plus p subscript ret comma mfr reb end subscript close parentheses times open parentheses reb subscript mnf end subscript close parentheses close parentheses over open parentheses reb subscript mfr end subscript plus DIR subscript ph end subscript close parentheses end fraction. (10)

DIR_ph_ = (p_ret, tot DIR_ − p_ret, mfr reb_)/(p_ret, pharm DIR_ − p_ret, tot DIR_) reb_mnf_ Equation 11: DIR subscript ph end subscript equals begin fraction open parentheses p subscript ret comma tot DIR end subscript minus p subscript ret comma mfr reb end subscript close parentheses over open parentheses p subscript ret comma pharm DIR end subscript minus p subscript ret comma tot DIR end subscript close parentheses end fraction times reb subscript mnf end subscript. (11)

We used equation 11 to estimate the collected pharmacy DIR (flow 5), DIR_ph_. We assumed the retained pharmacy DIR (flow 6) equals the collected pharmacy DIR (flow 5), and that the portion of pharmacy DIR passed on to the third-party payer (flow 7) is zero. We estimated the quantities in equation 11 in the following way:

▪ p_ret, tot DIR_: We estimated the proportion of total DIR retained to be 12.4 percent based on 2021 and 2022 PBM Annual Reports submitted to the state of Iowa, the two most recent years available at the time of the study (Iowa Insurance Division, 2020-2023).^28^
▪ p_ret, pharm DIR_: We assumed the proportion of pharmacy DIR retained by the PBM is 100 percent.
▪ p_ret, mfr reb_: We assumed the proportion of manufacturer rebate retained by the PBM is 0.4 percent for all plans, based on the GAO analysis of manufacturer rebates in Part D plans.
▪ reb_mnf_: We calculated the manufacturer rebate for each brand drug using the drug’s WAC, the SSR Health gross-to-net discount data, and the other modeled discounts the manufacturer gives to the supply chain (namely, the wholesaler discount).

Applying the above estimates to equation 11 yields the following. Both the pharmacy DIR and rebate are indexed by time t and drug i:

DIR_ph , i_^( t )^ = ( 0.137 ) (reb_mnf , i_^( t )^) Equation 12: DIR superscript open parentheses t close parentheses end superscript subscript ph comma i end subscript equals open parentheses 0.137 close parentheses times open parentheses reb superscript open parentheses t close parentheses end superscript subscript mnf comma i end subscript close parentheses. (12)

This methodology is discussed in greater detail in Appendix B.5. Based on our scan of the literature, estimating the DIR associated with specific brand drugs is a novel aspect of our methodology. A limitation in our approach to estimating DIR is that it does not capture any pharmacy DIR that the PBM passes along to the payer. This does not impact our calculation of pharmacy margins, but this omission may lead to overestimates of PBM margins, though in general, we expect that the DIR passed along to the payer is small relative to the total DIR that PBMs collect across all of their market segments (i.e., Medicare, Medicaid, and commercial markets).

### 3.3.2 Generic Drugs

For generic drugs, which are shown on the right side of Table 7, we computed margins largely using the same methodology as in Section 3.3.1. However, flows (10), (11), and (12) are omitted because drug manufacturers do not provide rebates to PBMs for generic drug products and SSR Health data, which we used to estimate net prices (including Medicaid rebates), was not available for generic drugs. Additionally, we used the FUL data to estimate PBMs’ reimbursement rates to pharmacies (flow 3). As with brand drugs, we estimated the flows over the period from 2020 through 2022.

Because manufacturers do not provide rebates to the PBM for generics, pharmacy DIR was estimated differently. Fein (2019) reported that the net value of pharmacy DIR paid to Part D plans was approximately eight percent of pharmacies’ gross profits in 2017. We used this as an estimate of the average pharmacy DIR assessed when a generic drug is dispensed. Thus, we reduced both the pharmacy sales price and the PBM acquisition cost by eight percent of (pharmacy sales price) – (pharmacy acquisition cost) to account for pharmacy DIR. As with brand drugs, we assumed that all of the DIR is retained by the PBM. Estimating DIR for generic drugs is a novel approach.

To estimate wholesalers’ net acquisition costs (flow 9), we compared WACs in IQVIA NSP to historical and current “Big Four” prices in the VA FSS price file (U.S. Department of Veterans Affairs, Office of Procurement, Acquisition and Logistics, 2023). Using the generic retail drugs that were listed in the FSS files, we formed groupings based on WAC quintiles, and then for each group, we calculated an average discount from WAC to the Big Four price. We applied these discounts to drugs in our sample based on their WAC quintile group; the resulting discounted WAC was the estimated net acquisition cost to wholesalers. For more details, see Appendix B.3.

## 3.4 Designing Weights for the Sample

We computed weights for our sample of 3,720 drugs so that the margins in the sample could be scaled up to the full target population in order to characterize the margins of all retail sales (excluding mail-order sales). Although Table 8 suggests that the sample largely reflects the characteristics of the target population, the sample was based on data availability rather than random selection, and thus unintended imbalance could exist between the sample and the target population of drugs. For example, products with more packaging options may be overrepresented since the sample was based on the availability of data at the 11-digit NDC level, and drugs with multiple packages (e.g., 30-pill bottles, 60-pill bottles) or marketed by multiple labelers (e.g., all made by the same manufacturer) will tend to have more 11-digit NDCs. As an attempt to correct for this, the weights were calculated using each drug’s sales of extended units, as reported in IQVIA NSP, since extended units would tend to be lower for a drug whose real utilization is distributed across multiple packages.^29^ Specifically, we broke the sample into strata s based on whether the drug is a brand or generic, whether the drug treats an acute or a chronic condition, and whether the API is measured in kg or IU. The API unit was used to define strata because, within the sample, API unit was found to have a statistically significant impact on the margin per package. For each sampled drug i in a given stratum s, we calculated the drug’s weight w_i_^( t )^ at time t using:

w_i_^( t )^ = (total extended units sold in stratum s at time t in population)/(total extended units sold in stratum s at time t in sample) Equation 13: w superscript open parentheses t close parentheses end superscript subscript i end subscript equals begin fraction open parentheses total extended units sold in stratum s at time t in population close parentheses over open parentheses total extended units sold in stratum s at time t in sample close parentheses end fraction. (13)

Based on the sample, the weighted sum of all expenditures in 2022 is equal to $234.8. This is highly similar to the total invoice sales in IQVIA NSP, which equals $249.6 billion for all retail drugs and retail channels (excluding mail pharmacies).

To calculate an intermediary x’s total margin M_x_ in dollars, we then summed the individual margins across all sampled drugs i and all time points t of interest (e.g., a given calendar year):

M_x_ = ∑_t_ ∑_i_ (P_i_^( t )^ w_i_^( t )^ Y_i , x_^( t )^) Equation 14: uppercase M subscript x end subscript equals sum from t equals 1 to n of open parentheses sum from i equals 1 to n of open parentheses P superscript open parentheses t close parentheses end superscript subscript i end subscript times w superscript open parentheses t close parentheses end superscript subscript i end subscript times Y superscript open parentheses t close parentheses end superscript subscript i comma x end subscript close parentheses close parentheses. (14)

where P_i_^( t )^ is the number of packages sold of the i^th^ drug at the time point t, and Y_i,x_ is the margin per package for the i^th^ drug at the time point t for the intermediary x. To calculate the total or aggregate margin percentage, we divided the intermediary’s total margin M_x_ by its total net sales:

% M_x_ = (M_x_)/(∑_t_ ∑_i_ (P_i_^( t )^ w_i_^( t )^ S_i , x_^( t )^)) Equation 15: percentage of uppercase M subscript x end subscript equals begin fraction open parentheses uppercase M subscript x end subscript close parentheses over open parentheses sum from t equals 1 to n of open parentheses sum from i equals 1 to n of open parentheses P superscript open parentheses t close parentheses end superscript subscript i end subscript times w superscript open parentheses t close parentheses end superscript subscript i end subscript times S superscript open parentheses t close parentheses end superscript subscript i comma x end subscript close parentheses close parentheses close parentheses end fraction. (15)

where S_i_^( t )^ is the net sales price per package for the i^th^ drug and for the intermediary x at the time point t. The margin per package m_x_ for a given intermediary x was computed by dividing the intermediary’s total margin M_x_ by the weighted total packages sold:

m_x_ = (M_x_)/(∑_t_ ∑_i_ (P_i_^( t )^ w_i_^( t )^)) Equation 16: lowercase m subscript x end subscript equals begin fraction open parentheses uppercase M subscript x end subscript close parentheses over open parentheses sum from t equals 1 to n of open parentheses sum from i equals 1 to n of open parentheses P superscript open parentheses t close parentheses end superscript subscript i end subscript times w superscript open parentheses t close parentheses end superscript subscript i end subscript close parentheses close parentheses close parentheses end fraction. (16)

## 3.5 Descriptive Analysis of Margins

We used descriptive statistics to characterize the margins of pharmaceutical supply chain entities. We applied the computed weights (see Section 3.4) to extrapolate from our sample of 3,720 drugs and to generate estimates for the full population of drugs sold through retail pharmacies. We compared intermediaries based on their weighted total margins in dollars across all drug sales, weighted aggregate margin percentage across all drug sales, weighted mean margins per package, and retained shares of total expenditures. We performed subgroup analysis based on drug characteristic (e.g., brand versus generic, acute versus chronic, biologic versus small molecule, short market tenure versus long market tenure, etc.). We also examined trends in these quantities for brand drug, generic drug, and all drugs, by intermediary, during the Q1 2020-Q4 2022 period.

## 3.6 Sensitivity Analysis

We performed two sensitivity analyses to assess the degree of uncertainty in the main findings. These analyses were conducted using the full sample of generic and brand drugs.

First, to assess the sampling error, we conducted a Monte Carlo analysis consisting of 1,000 bootstrap samples constructed by sampling the original dataset with replacement. We recalculated the main results for each bootstrap sample and then constructed empirical 95 percent confidence intervals by selecting the 2.5^th^ and 97.5^th^ quantiles from each main result’s empirical distribution.

Second, to assess the model uncertainty, we selected five key parameters and adjusted each in turn by increasing and then decreasing the parameter by 20 percent of its original assumed value. The adjusted parameters include: (a) the percentage of manufacturer rebate the PBM retains, (b) wholesalers’ discount off the WAC on generic drugs, (c) wholesalers’ discount off the WAC on brand drugs, (d) the mean administrative fee PBMs charge the third-party payers on a per-prescription basis, and (e) the proportion of gross profit that pharmacies pay PBMs as generic drug DIR.

20 As discussed in greater detail below, wholesalers’ discount off the WAC was assumed to be nine percent for brand drugs. For generic drugs, wholesalers’ discount off the WAC was estimated based on Federal Supply Service Schedule pricing data. See details below.

21 When calculating the weighted average copay in IQVIA PayerTrak, we excluded cash payments, since copays only apply to payments made with insurance.

22 The VA negotiates this price with manufacturers on behalf of all direct federal purchasers. The price is determined in part through negotiation but also through statute. For example, “[d]uring a multiyear contract period, an FSS may not increase faster than the net price charged to the most-favored commercial customer” (Congressional Budget Office, 2021).

23 Without estimating these discounts, wholesalers would have negative margins on nearly every drug since the WAC is generally higher than the NADAC (which approximates wholesalers’ net sale price). In our sample, the NADAC is 0.52 times the WAC for generic drugs and 0.96 times the WAC for brand drugs, based on median ratios of the NADAC per API unit to the WAC per API unit.

24 Drugs with no API data were not represented in the sample, and thus their margins could not be estimated. They were also excluded from our estimate of the universe of prescription retail drug sales. This exclusion likely has a small effect, as these NDCs make up less than 1 percent of drugs in IQVIA NSP.

25 The retail channel includes sales to independent pharmacies, chain stores, and food stores; mail pharmacy sales are classified separately in IQVIA NSP and were not included in retail sales for purposes of this study.

26 As discussed in greater detail below, for brand drugs, we assumed the wholesaler discount is 9 percent at all times t and for all NDCs i. For generic drugs, the wholesaler discount varies by year and NDC i and was estimated from VA FSS data.

27 Because PayerTrak does not contain 11-digit NDC, we used other characteristics (e.g., manufacturer, product name, molecule, formulation, launch date) to match PayerTrak records to NSP records. Among our sample, 82.1 percent of generic drugs (n=2,762) and 83.7 percent of brand drugs (n=297) successfully matched to PayerTrak. The average copays were only used for roughly 18 percent of the sample.

28 We used 2022 and 2023 Annual Reports, which provide data from 2021 and 2022, respectively. While data were available for 2020, we did not use these reports because “several PBMs did not submit annual reports in that year because they either unintentionally applied to be certified as a PBM or requested to voluntarily surrender their Iowa PBM certificate” (Iowa Insurance Division, 2020-2023).

29 The precise interpretation of extended units varies by drug, but it typically refers to the number of pills, mL of liquid, or grams of powder sold.