# 2 BACKGROUND

This study estimates the margins of retail drug supply chain intermediaries— wholesalers, pharmacies, and PBMs. The methodology we used for estimating supply chain margins requires data on acquisition costs of and revenues from goods sold. As described below in Section 3, margins of wholesalers, pharmacies, and PBMs are based primarily on price data available from several public and proprietary databases. We were able to estimate both acquisition costs and sales revenues on a per-drug basis by tracking data for individual drugs. This study does not provide analyses of margins of drug manufacturers or third-party payers/insurers. For manufacturers, we could not obtain manufacturing costs per drug. For third-party payers, revenues are based on premiums, which could not be disaggregated at the per-drug level, even when publicly traded companies made overall premium revenues available.

Nevertheless, because both manufacturers and third-party payers have drawn much attention due to ongoing concern regarding societal expenditures on prescription drugs and patient access, we briefly discuss recent findings regarding the revenues and roles of these intermediaries in the retail drug supply chain.

## 2.1 Third-Party Payers/Healthcare Plans

In 2021, the top 10 health insurance plan companies—commonly called third-party payers—wrote $561 billion in direct premiums, or 61.7 percent of the industry total of $910.5 billion (Federal Insurance Office, 2022). The top five companies accounted for 48 percent of the total direct premiums written.^11^ Third-party payers provide prescription drug insurance to anyone with a prescription drug plan. This includes most Medicare beneficiaries—commonly referred to as Part D insurance—and Medicaid beneficiaries, as well as individuals with private insurance obtained through an employer, the individual marketplace, or another pooled risk group. Prescription drug insurers have a formulary of drugs that are covered for their beneficiaries. Insurers and PBMs can negotiate rebates from drug manufacturers, which are shared with the payer or plan sponsor, in exchange for better formulary placement and benefit management. Estimating the margins of third-party payers is problematic because most insurers provide prescription coverage as part of an overall health insurance package (which includes inpatient and outpatient health care services), and it is difficult to separate the costs and revenues associated with prescription drug insurance from those of overall health insurance. Sood et al. (2017), estimated gross and net margins for insurers at 22 percent and 3 percent, respectively. However, their study, as mentioned above, relied heavily on the financial filings of publicly-traded companies, and for insurance companies, Sood et al. (2017) were unable to separate margins associated with medical claims from margins associated with pharmacy claims, since the two are combined in health insurers’ financial results.

## 2.2 Pharmacy Benefit Managers

PBMs negotiate with manufacturers on behalf of insurers to secure better deals on covered drugs, usually in the form of rebates from manufacturers. They also negotiate with pharmacies to set the amount that an insurance company will reimburse a pharmacy for drugs (Commonwealth Fund, 2019). In addition to rebate and reimbursement negotiations, PBMs’ revenues result from providing such services as account management, claims processing, eligibility management, formulary management, mail-order pharmacy, member services, plan implementation and changes, and utilization management (Burns, 2022). The three largest PBMs, CVS Health/ Caremark, Cigna/ Evernorth/ Express Scripts, and UnitedHealth/ OptumRx, account for 79 percent of the market for PBM services; the six largest occupy 96 percent of the market (Table 1). The remaining 4 percent of the PBM market is served by 60 smaller firms.

Table 1 Market Shares of the Six Largest PBMs in the United States

PBM | Market Share
CVS Health / Caremark | 33%
Cigna / Evernorth / Express Scripts | 24%
UnitedHealth / OptumRx | 22%
Humana Pharmacy Solutions | 8%
Prime Therapeutics / Magellan Rx | 5%
MedImpact Healthcare Systems | 4%

Source: Fein (2023)

PBMs have been criticized for keeping a percentage of manufacturer rebates and for “spread pricing,” in which PBMs charge insurance companies more than they reimburse pharmacies for a drug and keep the difference. Rebates are used almost exclusively with brand drugs^12^ with marketed competitors and thus partly counteract high list prices while serving as an important PBM revenue source. With generic drugs, rebates are typically not offered by manufacturers because generics’ list prices are substantially lower, so PBMs earn revenue through spread pricing. The difference between the payment the PBM receives from the insurer and the payment it makes to the pharmacy is referred to as the “spread.” The dollar amounts of rebates are confidential, as are PBMs’ price spreads. As the middleman, PBMs have a large influence on drug prices, but their pricing is particularly opaque (Stomberg, 2021).

Overall, PBM margins at the company level have been estimated at between 3 and 6 percent by various researchers in aggregate; however, there is significant variation at the drug level. According to an analysis by Metcalf and Weinberg (2017), PBMs can minimize their perceived margin percentages by counting as revenue the full value of all the drugs that they contract for on behalf of their clients, rather than the final price after accounting for rebates and discounts. Though this is an acceptable accounting practice, it artificially inflates the denominator of the fraction representing PBMs’ operating margins (Metcalf & Weinberg, 2017).^13^ Without these artificially inflated revenue figures, the operating margins of Express Scripts and CVS more than double to 15 and 10 percent, respectively (Metcalf & Weinberg, 2017).

Manufacturer rebates have been one method PBMs have used to increase their margins, though there is evidence that this practice is diminishing (United States Government Accountability Office, 2019). PBMs say that the rebates they negotiate from manufacturers benefit plan sponsors and customers, and that higher drug costs are due to manufacturer price increases (Eyles, 2022). Nevertheless, these rebates are at times paid by manufacturers to the PBM as a quid pro quo for an advantage, such as inclusion on a formulary tier that advantages the manufacturer over competitors (Shepherd, 2019; Cole, et al., 2019; Seeley & Kesselheim, 2019). Manufacturers are incentivized to provide these rebates because higher formulary placement can lower beneficiaries’ copays, which in turn, can drive up their drug’s utilization. In commercial plans, for example, out-of-pocket costs are lower because they are often based on the formulary tier rather than the plan’s negotiated drug price.^14^ In Medicare Part D out-of-pocket costs are a percent of the list price of a drug. A portion of the manufacturer rebate is retained by the PBM, and the remainder is passed along to the plan.

PBMs margins are also derived from administrative fees, which have traditionally been payments the insurance plan makes to the PBM (though some PBMs are also charging fees to manufacturers, possibly to make up for diminishing rebates). PBMs often charge a fixed administrative fee per prescription associated with a pass-through contract. Pass-through contracts were designed as an alternative to traditional PBM contracts and were intended, in part, to reduce spread pricing. In pass-through contracts, the third-party payer pays the PBM the same price for drugs as the PBM reimburses the pharmacy, thereby eliminating any spread between the PBM’s sale and acquisition costs. In some cases, however, pass-through contracts can lead to higher prices for the third-party payer. For example, the PBM may voluntarily pay pharmacies higher prices on pass-through claims (leading to higher prices for the third-party payer), thereby allowing the PBM to pay lower prices to the pharmacy on its traditional contracts. This practice may allow the PBM to increase its price spread on traditional contracts while still collecting administrative fees on pass-through contracts (RxBenefits, 2020). In general, PBMs’ market dominance can provide a level of flexibility that allows them to generate margins despite attempts to reduce spending, like pass-through contracts.

The research mentioned throughout this section highlight the fact that complexities within the pharmaceutical supply chain have led to anomalous outcomes, such as manufacturers losing revenue despite raising list prices, and PBMs gaining revenue by incentivizing consumers to choose a more expensive brand drug over a generic. A detailed catalogue of the many contractual mechanisms that some PBMs have been using—or been accused by critics of using—is beyond the scope of this study. That said, PBMs have been retaining some of the rebates that they negotiate from manufacturers (rebates that could be passed on entirely to insurers or customers), protecting the opacity of their contract terms, engaging in spread pricing, patient steering, and other similar practices, and have been successfully sued by states and pharmacy networks for a variety of overcharges and anti-competitive actions (Meador, 2011; Feldman, 2020; Kakani, et al., 2020; Trish, et al., 2022; Myshko, 2023). Their influence over drug prices and their position of influence with regard to pharmacies, health plans, and manufacturers, have made PBMs a target of federal and state legislators seeking to ameliorate the financial burden on society of high prescription drug expenditures.

Some state governments have taken the lead on regulating the PBMs, especially after the 2020 Supreme Court ruling in Rutledge v. Pharmaceutical Care Management Association (PCMA) confirmed that states have the right to regulate PBMs (Fuse-Brown & McCuskey, 2020). So far in 2023, 15 states have enacted 18 laws, and in 2022 alone, 12 states enacted 19 pieces of legislation targeted at PBMs (National Academy for State Health Policy, 2023; Myshko, 2023). These laws are focused on eliminating gag clauses, requiring price reporting, and requiring PBMs to register with the state, among other reforms (see Appendix A for a compendium of state-level PBM regulations).

It is possible that the increasing attention that PBMs have experienced in recent years may have influenced some to modify their revenue enhancement strategies away from spread pricing and rebate retention by becoming vertically integrated with health insurers and/or pharmacies. The three largest PBMs have merged with or been acquired by health insurers— Express Scripts by Cigna in 2018 and CVS Caremark with Aetna in 2017; Optum Health evolved from United Health’s 2005 acquisition of the regional insurer PacifiCare, which had an in-house PBM. Guardado (2023) analyzed the status of vertical integration of PBMs and commercial drug insurers at the national, state, and metropolitan statistical area (MSA) levels. Guardado (2023) found that, “Nationally, 70 percent of drug lives were covered by a vertically integrated insurer in 2021.” At the state level, integrated PBM/insurer companies covered a total of 63 percent of covered lives, although the figures ranged from six percent in South Dakota to 97 percent in Utah. Similarly, across 383 MSAs, 63 percent of covered lives were served by an integrated PBM/insurance entity. This vertical integration provides the insurance division of the merged entity with more direct oversight of PBM functions that affect insurance revenues (e.g., rebate pass throughs; “utilization management strategies” such as prior approvals and step therapies). Integrated PBM/insurance entities that provide PBM services to outside insurers—four of the top 10 vertically integrated PBMs service other insurers in addition to their own—may have potential competitive advantages over the 30 percent of non-integrated PBMs (Guardado, 2023).^15^ Vertical integration also enables insurers to avoid potentially contentious negotiations and disputes with PBMs, such as the years-long dispute between ExpressScripts and Anthem. Although Anthem had originally sued ExpressScripts for overbilling, ultimately, ExpressScripts won a $15 billion judgment from Anthem, Anthem, Inc. v. Express Scripts, Inc., 16-cv-2048 (ER) (S.D.N.Y. Mar. 8, 2023).

Recently, Congress has proposed several bipartisan bills aimed at regulating how PBMs function within the retail drug supply chain. These include Senate bill 127, the Pharmacy Benefit Manager Transparency Act of 2023, which aimed to ban certain PBM tactics, such as spread pricing and clawback fees, and the Modernizing and Ensuring PBM Accountability Act (MEPA), which sought to delink PBM income from prescription drug prices, required enhanced reporting and PBM audits among other measures, though these proposals were not enacted.

Another source of PBM revenue is DIR fees, which the PBM assesses to the pharmacy. These fees may arise, for example, if PBM reimbursements exceed negotiated contract rates. DIR also can include penalties based on pharmacy metrics like generic dispense rates, as well as network participation fees that that PBM charges the pharmacy.

## 2.3 Pharmacies

There are a total of 61,715 pharmacies in the United States of which 37,954 (61.5 percent) are chain stores, 23,521 (38.1 percent) are regional franchises or independently owned pharmacies, and 240 (0.4 percent) are government pharmacies based on a Geographic Information System (GIS) analysis of consumer access to pharmacies by Berenbrok, et al. (2022). Pharmacies typically purchase medications from wholesalers and derive their margins from reimbursements from PBMs. The reimbursements PBMs provide pharmacies often are based on an ingredient cost plus a fixed dispensing fee that the pharmacy charges for each filled prescription (for example, see, (Centers for Medicare & Medicaid Services, 2022)). Overall, U.S. pharmacy prescription sales were reported to provide a gross margin of 21.0 percent, net of rebates, in 2018 (Fein, 2019). Generic drugs return a higher margin percentage to pharmacies than brands, but because generics are so much cheaper than brands, the value of these margins are still lower than for brands on a per drug basis. In 2018, the generic dispensing rate for all pharmacies was 85.6 percent. The comparative margins for brand versus generics in 2012 were estimated by Drug Channels as 9.6 percent and 51.0 percent, respectively (Fein, 2017).

## 2.4 Wholesalers

Wholesalers acquire drugs from manufacturers at the wholesale acquisition cost (WAC, also known as the list price) from which is subtracted a variety of fees and discounts, such as handling fees or ancillary “prompt payment” discounts for submitting early payment (Stomberg, 2021). The three largest pharmaceutical wholesalers are McKesson, AmeriSourceBergen, and Cardinal Health. Combined, these companies account for approximately 90 percent of all wholesale drug activity in the U.S. (Seeley, 2022). A recent examination of wholesalers’ role in the supply chain by Seeley (2022) stated, “[t]he difference between what wholesalers pay for brand-name drugs and what they charge pharmacies can represent a major source of revenue for wholesalers, although it remains a very small fraction of overall brand-name drug prices and spending.” However, “[i]n most branded-drug markets, wholesalers act as price-takers, often selling at the same discounted WAC that they buy at, such as WAC minus 5 percent” (Seeley, 2022). Despite being price takers and having low average margin percentages, the high price of brand drugs still can generate substantial revenues for wholesalers.

Wholesalers earn additional revenues from handling generic drugs. Even though the prices of most generic drugs are significantly lower than brands, generic drugs comprise 90 percent of all retail prescriptions filled in the United States. Seeley (2022) estimated the range of wholesaler markups of generic drugs between 10 percent and 15 percent, which would generally equate to roughly $5-10 for a typical package (assuming a per-package cost to the wholesaler of roughly $60).

Larger wholesalers also derive revenue through horizontal and vertical expansion, which allows them to provide other services, such as: negotiating improved rebate sharing from PBMs on behalf of independent pharmacies or pharmacy chains; offering proprietary drug distribution data to other supply chain intermediaries; drug repackaging; supplying medical devices, other medical products, and information technology (IT) platforms; and, increasingly, distributing specialty drugs.

## 2.5 Manufacturers

Generally, drug manufacturers conduct the research and development necessary to gain regulatory approval and bring new drugs to market. They also incur costs to acquire raw materials and to manufacture the drug. Manufacturers establish list prices for their products and have attracted public and regulatory attention due to rising drug prices and consumer expenditures.^16^ Although manufacturers receive a plurality of drug expenditures, their operating expenses and risk levels are likely to far exceed those of other intermediaries of the pharmaceutical supply chain. Sood et al. (2021) calculated the adjusted “excess returns” at the firm level from 2013 through 2018 for 21 of the largest drug and biotech companies, as well as some of the largest wholesalers, and PBMs/insurers/pharmacies. They defined “excess returns” as follows: “A firm makes ‘excess returns’ if it generates more profits than expected given the risk associated with their investments…. Excess returns were therefore calculated as the difference between return on invested capital (ROIC) and the expected returns given risk, which is known as the weighted average cost of capital (WACC).” They considered the average excess returns of S&P 500 companies as a benchmark. Their results showed manufacturers having the lowest aggregate rate of adjusted excess returns (1.7 percent), which was less than half the rate of adjusted excess returns realized by S&P 500 companies (Table 2). This contrasted with insurers/PBMs/retailers (i.e., retail pharmacies), who collectively had average excess returns of 5.9 percent, and wholesalers, who were at 8.1 percent (Sood, et al., 2021).^17,^ ^18^

Table 2 Excess Returns in the Drug Supply Chain, 2013 – 2018

Supply Chain Segment | Average Unadjusted Excess Returns 2013 - 2018 ^[a]^ | Average Adjusted Excess Returns 2013 - 2018 ^[b]^
Pharmaceutical Manufacturers | 4.7% | 1.7%
Biotech Manufacturers | 13.1% | 9.6%
Wholesalers | 9.3% | 8.1%
PBMs/Insurers/Retailers | 5.9% | 5.9%
S&P 500 | 4.2% | 3.6%

Source: Sood, et al. (2021)

[a] R&D spending included as an expense.

[b] R&D spending treated as part of investment capital.

In an earlier study, Sood et al. (2017), also examined 2015 U.S. Securities and Exchange Commission (SEC) filings by the largest firms at various levels of the supply chain, as well as data from the National Average Drug Acquisition Cost (NADAC) database and the National Average Retail Price (NARP) dataset from the Centers for Medicare and Medicaid (CMS) for 2013. Table 3 presents the gross and net margins they calculated for five supply chain sectors. The authors then used these results to calculate the distribution of a hypothetical $100 expenditure at a retail pharmacy for prescription drugs in the United States (Table 4). They stated, “…roughly $17 goes to drug production costs, [an additional] $41 accrues to the manufacturers (a third of which is net profit), and $19 accrues to insurers ($3 of which is net profit). PBMs keep about $5 ($2 net profit), pharmacies keep $15 ($3 net profit), and wholesalers keep about $2 (30 cents net profit). Total net profit on a $100 expenditure is $23, of which $15 is captured by manufacturers and the remaining $8 by intermediaries.” (Sood, et al., 2017) The authors noted that their study had several limitations, not the least of which is reliance on publicly filed financial statements that can be affected by numerous factors unrelated to financial activity within the supply chain.^19^

Our current study was designed in part to avoid many of the limitations noted by Sood et al. (2017), by relying on sales data at the drug level, which, while they may have occasional reporting errors or omissions, do not suffer from the same disadvantages as firm-level financial data.

Table 3 Average Gross and Net Margins for Each Sector, Individual Firm Margins Weighted by U.S. Sales (Sood et al., 2017)

Sector | All Drugs | | Brand Only | | Generic Only
Sector | Gross Margin | Net Margin | Gross Margin | Net Margin | Gross Margin | Net Margin
Manufacturer | 71.1% | 26.3% | 76.3% | 28.1% | 49.8% | 18.2%
Wholesaler | 3.7% | 0.5% | 1.0% | NA | 18.5% | NA
Insurer | 22.2% | 3.0% | 22.2% | NA | 22.2% | NA
PBM | 6.3% | 2.3% | 2.0% | NA | 8.0% | NA
Pharmacy | 2.1% | 4.0% | 3.5% | NA | 42.7% | NA

Source: Sood, et al. (2017)

NA = Not available

Table 4 Distribution of $100 Expenditure Entering the Supply Chain

Sector | Cost of Production | Retained Earnings | Net Profit
Manufacturer | $17 | $41 | $15
Wholesaler | N/A | $2 | $0.30
Insurer | N/A | $19 | $3
PBM | N/A | $5 | $2
Pharmacy | N/A | $15 | $3
Total | $17 | $82 | $23.30

Source: Sood, et al. (2017).

N/A indicates not applicable.

In a similar vein, Van Nuys et al. (2021) focused on the distribution of net expenditures for a single class of products, insulin, the cost of and access to which had become a national and global public health concern (Beran, et al., 2018) (Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health & Human Services, 2022). Van Nuys et al. (2021) found that “[b]etween 2014 and 2018, mean list prices of 32 insulin products increased by 40.1 percent (from $19.6 to $27.5), while mean net prices received by manufacturers decreased by 30.8 percent (from $10.5 to $7.3). … [T]he share of a hypothetical $100 insulin expenditure accruing to manufacturers decreased by 33.0 percent (from $69.7 to $46.7) and the share accruing to health plans decreased by 24.7 percent (from $13.8 to $10.4). The share of insulin expenditures retained by [PBMs] increased by 154.6 percent (from $5.6 to $14.4), the share retained by pharmacies increased by 228.8 percent (from $6.2 to $20.4), and the share retained by wholesalers increased by 74.7 percent (from $4.6 to $8.1)” (Van Nuys, et al., 2021). These results of Van Nuys et al. (2021) are summarized in Table 5.

Table 5 Distribution of $100 Expended on 32 Insulin Products, 2014 and 2018

Sector | 2014 | 2018 | Δ | Percent Δ
Manufacturer | $69.71 | $46.73 | −$22.98 | −33.0%
Wholesaler | $4.63 | $8.09 | +$3.46 | +74.7%
Insurer | $13.82 | $10.40 | −$3.42 | −24.7%
PBM | $5.64 | $14.36 | +$8.72 | +154.6%
Pharmacy | $6.21 | $20.42 | +$14.21 | +228.8%
Mean List Price | $19.60 | $27.45 | +$7.85 | +40.1%
Mean Net Price to Manufacturers | $10.53 | $7.29 | −$3.24 | −30.8%

Source: Van Nuys, et al. (2021)

The authors noted one limitation to their study was a “lack [of] complete time-series data on transaction prices at each step of the distribution system…” and that “therefore the split of excess earnings among intermediaries may be imprecise.” They stated that “our results are best interpreted as suggesting trends in insulin markets generally rather than as providing a precise picture of a particular insulin market.” (Van Nuys, et al., 2021)

These studies by Sood et al. (2017; 2021), and Van Nuys et al. (2021) demonstrate important trends and anomalies in the drug supply chain. They represent three distinct assessments: (1) an attempt to use financial data from a sample of individual firms in each sector, coupled with sales data, to calculate aggregated gross and net margins in each supply chain sector (Sood, et al., 2017); (2) an attempt to derive average risk-adjusted “excess returns” within each supply chain sector (Sood, et al., 2021); and (3) focusing on one high profile drug market (insulin) to reveal price increases over five years and how distribution of expenditures for insulin products shifted across supply chain sectors during that time (Van Nuys, et al., 2021).

This study did not examine margins for manufacturers because data on manufacturers’ acquisition costs for ingredients were not available at the drug level, and there may be debate about the extent to which manufacturers’ margins should account for the cost of drug development. However, this study contributes new information by estimating the proportion of expenditures manufacturers retain, the net prices at which manufacturers sell drugs to wholesalers, and the magnitude of rebates or other DIR paid by manufacturers and pharmacies to PBMs.

11 The top five health insurance companies by direct premiums written in 2021 were UnitedHealth Group, Elevance Health (Anthem), Centene Corp., Humana, and Health Care Services Corp. (HCSC). CVS Health was sixth (Federal Insurance Office, 2022).

12 Data in SSR Health suggest that biosimilars provide rebates to PBMs. Biosimilars are biologic products that, like generic drugs, are approved based on comparison with a reference listed drug (aka originator biologic). Unlike traditional small molecule generic drugs, biosimilars are given brand names and may undergo large-scale clinical trials.

13 The authors gave an explanatory example of the distinction between agents facilitating a transaction and principals participating in a transaction: “When Expedia books a $100 hotel room, it typically counts as revenue only the sum that it pockets through commissions and other fees and calculates its profit margins from that. Walgreens and other retailers, by contrast, account for the full value of many of the goods they sell in their top-line figures because, among other factors, they take control of the goods before selling them. For the most part, the big PBMs treat themselves as principals when they tally their sales – which means they book the entire value of drug transactions as revenue” similar to Walgreens and other retailers (Metcalf & Weinberg, 2017).

14 For this reason, a more expensive brand drug with high formulary placement may receive more utilization than a drug that costs the plan less but has lower formulary placement.

15 Guardado (2023) states: “An important question is whether non-vertically integrated insurers face higher PBM prices, which could then translate to higher premiums.”

16 Two major pieces of legislation—Hatch-Waxman and the 2009 Biologics Price Competition and Innovation Act (BPCIA)—were enacted mainly to foster competition in brand drug markets in response to the high prices set by manufacturers.

17 The authors attributed the high rate of adjusted excess returns among biotech companies (9.6 percent) to the approval and marketing of several blockbuster biologics.

18 Sood et al. (2021) noted several limitations to this study, including: (1) reliance on data from financial statements, “which can be misreported or manipulated through standard accounting methods”; (2) inability to disaggregate excess returns of PBMs from insurers and pharmacies/retailers due to vertical integration of many of the larger PBMs with retail drug chains and insurers; (3) the excess returns of pharmaceutical firms include returns on all investments, not just pharma revenues; and (4) reporting of rebates “may lag sales and therefore cause revenues to be overstated for manufacturers or understated for insurers/PBMs/retailers.”

19 “Key data are not always publicly available, and even the data presented in financial statements may be reported in inconsistent and opaque ways. Some of the largest players in certain sectors are privately held and make no financial data public. Thus, all our estimates are to some extent incomplete and inexact” (Sood, et al., 2017).