# 1 INTRODUCTION

Prescription drug spending in the United States totaled $603 billion in 2021, comprising 18 percent of total national healthcare spending (Parasrampuria & Murphy, 2022). From July 1, 2021, to June 30, 2022, the prices of 1,216 drugs increased at rates higher than inflation during that period (Bosworth, et al., 2022). Eight in 10 Americans say that the costs of prescription drugs are unreasonable, and 26 percent say they have trouble affording their drugs (Kirzinger, et al., 2023). Further, the increasing levels of pharmaceutical expenditures drove per capita annual spending on medications in the United States to $1,432 in 2021 (Organisation for Economic Cooperation and Development, 2023). This was 37 percent greater than Germany’s 2021 expenditure ($1,042), 66 percent greater than Canada’s ($865), and 78 percent more than Switzerland’s ($803), the next three highest spending countries per capita in 2021 (Organisation for Economic Cooperation and Development, 2023).

Effective policies that broaden access to drugs and reduce drug costs while encouraging innovation must be predicated on identifying the actors and mechanisms that raise drug costs without increasing their value to the end user. However, assessing the margins of entities throughout the pharmaceutical supply chain is complicated by the lack of transparency surrounding the distribution of payments among these entities. The negotiations between pharmacy benefit managers (PBMs), pharmacies, health plans, wholesalers, and manufacturers (Figure 1) remain private, and the terms of their contracts are confidential. For example, health plans may know how much they reimburse for a drug, but they often do not know the actual net cost of that drug, which is dependent on the size of the rebates and discounts the PBM negotiates with the manufacturer, ostensibly on behalf of the payer (Feldman, 2020).

Figure 1 Schematic of Medicine and Dollar Flows Among Supply Chain Principals

Note: This simplified graphic does not represent every relationship and intermediary in the supply chain or marketplace.

Figure 1 shows the flow of medicine and dollars between manufacturers and patients. Medicine goes from the manufacturer to a wholesaler, then to a pharmacy, and then to a patient. Patients in return give money to the pharmacy and their health plan, both of which then transfer money to and from pharmacy benefit managers. Pharmacies also give money to the wholesaler, who in turn give money to the manufacturer. Dollars also flow from manufacturers to pharmacy benefit managers.

Source: PBM Accountability Project (undated)

Thus, to develop effective and fair policies that reduce drug prices, it is important to understand at which points along the pharmaceutical supply chain are “excess profits” generated.^7^ Gaining a better understanding of the magnitude of these intermediaries’ margins is pertinent to broadening access and affordability to prescription drugs and lowering national expenditures on prescription drugs, which have reached new heights over the past decade (Rome, et al., 2022).

Previous literature has examined the complexities of the pharmaceutical supply chain, evaluated policy options intended to lower drug expenditures, and developed empirical models to explain how payments flow through the system (Dusetzina, et al., 2017; Feng & Maini, 2023). In addition to limiting manufacturers’ price increases to inflation and enabling the government to negotiate prices for some of the highest expenditure drugs, proposed policy interventions have included: 100 percent point-of-sale rebating (i.e., giving rebates to consumers); pricing and rebate transparency; giving PBMs fiduciary duties to health plans and/or beneficiaries; prohibiting PBMs from patient steering and clawing back reimbursements given to pharmacies; regulation of DIR; registration of PBMs with state pharmacy boards; oversight of formulary development; and requiring periodic audits of PBMs.^8^ That said, Meador (2011) notes the following when discussing the National Community Pharmacists Association’s Pharmacy Benefit Manager Licensure and Solvency Protection Act (NCPA Act):

The ideal reforms would combine the strict pricing and disclosure requirements of the NCPA Act with clear standards that explicitly and directly prohibit the anti-competitive business practices frequently complained of and stronger mechanisms to pass on savings to the consumer. It should be noted that there is a caveat to this arrangement: even with reform in the PBM industry, drug prices could remain high because of manufacturers. (Meador, 2011)

## 1.1 Study Objectives

Using several public and proprietary data sources, this study estimates the margins of three intermediaries within the retail pharmaceutical drug supply chain^9^—wholesalers, pharmacies, and PBMs—for prescription drugs, defined at the 11-digit National Drug Code (NDC) level. By constructing a dataset that follows drugs from manufacturer to patient, we are able to analyze how certain drug characteristics impact the margins of these intermediaries. We consulted with two subject matter experts to confirm the validity of our approach, with the usual caveats regarding the possibility and potential impacts of data insufficiencies.

The analysis centers on prescription drugs sold through the retail channel (i.e., independent pharmacies, chain stores, and food stores, except mail-order pharmacies).^10^ These retail drugs are covered under Medicare Part D plans, Medicaid, as well as by private insurers; hence, they represent the confluence of private and public interests in the prescription drug marketplace across all levels of the supply chain. Among federally sponsored prescription drug programs, drugs in the Medicare Part D market most closely resemble the much larger retail private prescription drug insurance market. In 2021, federal spending on Part D was $96 billion (Congressional Budget Office, 2021), or 21.4 percent of the $421 billion expended nationally for retail drugs (Parasrampuria & Murphy, 2022). Medicaid net spending for outpatient drugs in 2021 was $38.1 billion or 9.0 percent (Park, 2022). We separately assess brand and generic drugs because the cost and utilization of these types of drugs are different. Generics and biosimilars accounted for 91 percent of the prescriptions filled in the United States in 2021 but represented just 18.2 percent of prescription expenditures (Association for Accessible Medicines, 2022).

Our study aims to answer the following research questions:

1. How are total expenditures on retail drugs distributed throughout the supply chain across manufacturers, wholesalers, pharmacies, and PBMs?
2. What are the margins of wholesalers, pharmacies, and PBMs on retail drugs?
3. Do margins vary:
  a. Between generic and brand name drugs?
  b. Whether a drug treats acute or chronic conditions?
  c. Whether a drug is a biologic?
  d. How long a drug has been marketed (i.e., “drug tenure”)?
4. What has been the trend in intermediary margins between 2020-2022 for brand name drugs?

7 The Oxford Dictionary of Economics defines “excess profits” as “Profits which are above the level necessary to retain an entrepreneur in the current line of business. Opinions that profits are excessive are usually based on comparisons, either with the rate of return on capital obtainable in other industries with a comparable degree of risk, or with the past profits of the same company” (Black, et al., 2009).

8 Further discussion of these proposed policy interventions can be found in Appendix A: Compendium of State Statutes Addressing PBM Issues.

9 The retail pharmaceutical drug supply chain refers to the supply chain of those prescription drugs obtained at independent pharmacies (excluding mail pharmacies), chain stores, and food stores by patients, who then self-administer the drug. This is distinct from drugs administered during hospitalizations or drugs administered by healthcare professionals in outpatient settings.

10 Over-the-counter (OTC) medications were excluded because they are not handled by the same supply chain intermediaries since they generally are not covered by insurance.