# APPENDIX C ADDITIONAL ANALYSES

## C.1 Study Sample Characteristics

Table C - 1 shows the number of unique molecule-formulation-manufacturer combinations in our sample. Table C - 2 presents the number of drugs and observations in the sample, by time period.

Table C - 1 Unique Molecule-Formulation-Manufacturer Combinations, 2022

Drug Characteristic | Number of Molecule-Form-Manufacturer Combinations
Drug Characteristic | 2020 | 2021 | 2022 | 2020-2022
Brand | 122 | 107 | 97 | 136
Generic | 1,113 | 1,267 | 1,433 | 1,540
Long Tenure ^[a]^ | 477 | 538 | 608 | 666
Short Tenure | 804 | 885 | 975 | 1,163
Biologic | 14 | 13 | 13 | 14
Small Molecule | 1,220 | 1,361 | 1,517 | 1,661
Acute Condition | 436 | 491 | 542 | 598
Chronic Condition | 808 | 896 | 1,001 | 1,090

[a] “Long” tenure refers to having more than 13 years or more than 9 years on the market for biologics and small molecules, respectively.

Table C - 2 Number of Drugs and Observations in Sample, by Time Period

Time Period | Number of Drugs (Number of Observations of Drugs) ^[a]^
Time Period | Type of Drug | Acute | Chronic | Biologic | Small Molecule | Long Tenure ^[b]^ | Short Tenure
2020-2022 | Brand | 83; (679) | 272; (2,251) | 31; (314) | 324; (2,616) | 203; (1,532) | 194; (1,398)
2020-2022 | Generic | 965; (7,882) | 2,400; (20,178) | 0 ^[c]^; (0) | 3,365; (28,060) | 2,363; (17,310) | 1,257; (10,750)
2020-2022 | All Drugs | 1,048; (8,561) | 2,672; (22,429) | 31; (314) | 3,689; (30,676) | 2,566; (18,842) | 1,451; (12,148)
2020 | Brand | 64; (222) | 249; (832) | 27; (103) | 286; (951) | 167; (562) | 166; (492)
2020 | Generic | 690; (2,357) | 1,700; (5,540) | 0 ^[c]^; (0) | 2,390; (7,897) | 1,565; (4,894) | 894; (3,003)
2020 | All Drugs | 754; (2,579) | 1,949; (6,372) | 27; (103) | 2,676; (8,848) | 1,732; (5,456) | 1,060; (3,495)
2021 | Brand | 68; (235) | 203; (716) | 28; (104) | 243; (847) | 136; (493) | 136; (458)
2021 | Generic | 782; (2,576) | 1,972; (6,814) | 0 ^[c]^; (0) | 2,754; (9,390) | 1,794; (5,822) | 1,043; (3,568)
2021 | All Drugs | 850; (2,811) | 2,175; (7,530) | 28; (104) | 2,997; (10,237) | 1,930; (6,315) | 1,179; (4,026)
2022 | Brand | 67; (222) | 184; (703) | 27; (107) | 224; (818) | 140; (477) | 123; (448)
2022 | Generic | 873; (2,949) | 2,230; (7,824) | 0 ^[c]^; (0) | 3,103; (10,773) | 1,975; (6,594) | 1,188; (4,179)
2022 | All Drugs | 940; (3,171) | 2,414; (8,527) | 27; (107) | 3,327; (11,591) | 2,115; (7,071) | 1,311; (4,627)

[a] Table presents number of unique drugs (i.e., 11-digit NDCs) in the sample for the given time period and with the given characteristic. Value in parentheses is number of unique observations of drugs (i.e., month and 11-digit NDC) in the sample.

[b] “Long” tenure refers to having more than 13 years or more than 9 years on the market for biologics and small molecules, respectively.

[c] The sample did not contain any biosimilar drugs.

## C.2 Share of Expenditures, Detailed Tables

Table C - 3 presents the dollar values associated with the percentages of expenditures retained for each drug characteristic shown in Figure 4. For wholesalers, pharmacies, and PBMs these retained expenditures equal the total aggregate margins discussed in Section 4.2.2 and Section 4.2.3.

Table C - 3 Retained Expenditures of Retail Drugs, by Intermediary and Drug Characteristic, 2022 (Billions) ^[a]^

Type of Drug | Intermediary | Overall | Acute | Chronic | Biologic | Small Molecule | Long Tenure ^[b]^ | Short Tenure ^[b]^
Brand | Manufacturer | $124.6 | $27.6 | $97.1 | $27.5 | $97.1 | $45.5 | $79.1
Brand | Wholesaler | $14.1 | −$0.7 | $14.9 | $5.7 | $8.5 | $1.77 | $12.4
Brand | Pharmacy | −$0.5 | $2.9 | −$3.4 | −$1.5 | $0.9 | $8.89 | −$9.42
Brand | PBM | $30.7 | $6.4 | $24.3 | $9.2 | $21.5 | $11.1 | $19.6
Brand | Sample Size ^[c]^ | 925 | 222 | 703 | 107 | 818 | 477 | 448
Generic | Manufacturer | $13.9 | $6.4 | $7.5 | ^[d]^ | $13.9 | $7.58 | $6.32
Generic | Wholesaler | $9.3 | $4.7 | $4.5 | ^[d]^ | $9.3 | $3.96 | $5.30
Generic | Pharmacy | $12.7 | $5.3 | $7.4 | ^[d]^ | $12.7 | $6.31 | $6.43
Generic | PBM | $29.9 | $12.8 | $17.1 | ^[d]^ | $29.9 | $14.9 | $15.1
Generic | Sample Size ^[c]^ | 10,773 | 2,949 | 7,824 | 0 | 10,773 | 6,594 | 4,179
All Drugs | Manufacturer | $138.5 | $34.0 | $104.5 | $27.5 | $111.0 | $53.1 | $85.4
All Drugs | Wholesaler | $23.4 | $4.0 | $19.4 | $5.7 | $17.7 | $5.73 | $17.7
All Drugs | Pharmacy | $12.2 | $8.2 | $4.0 | −$1.5 | $13.7 | $15.2 | −$2.99
All Drugs | PBM | $60.6 | $19.2 | $41.4 | $9.2 | $51.4 | $26.0 | $34.7
All Drugs | Sample Size ^[c]^ | 11,698 | 3,171 | 8,527 | 107 | 11,591 | 7,071 | 4,627

[a] Table presents weighted population estimates. Due to rounding, the totals for a given set of characteristics may not sum to the overall total for all drugs.

[b] “Long” tenure refers to having more than 13 years or more than 9 years on the market for biologics and small molecules, respectively.

[c] Sample size is the number of unique observations of drugs (i.e., month and 11-digit NDC) in the sample.

[d] Cannot be estimated because the sample did not contain any biosimilar drugs.

Table C - 4 shows the share of expenditures that each intermediary retains, by various drug characteristics.

Table C - 4 Retained Share of Total Expenditures on Retail Drugs, by Intermediary and Drug Type, 2022 ^[a]^

Type of Drug | Intermediary | Acute | Chronic | Biologic | Small Molecule | Long Tenure ^[b]^ | Short Tenure ^[b]^
Total Expenditures (Billion $) | | $65.4 | $169.3 | $40.9 | $193.9 | $100.0 | $134.8
Brand | Manufacturer | 76.2% | 73.1% | 67.2% | 75.9% | 67.7% | 77.8%
Brand | Wholesaler | −2.0% | 11.2% | 13.9% | 6.6% | 2.6% | 12.2%
Brand | Pharmacy | 8.0% | −2.6% | −3.6% | 0.7% | 13.2% | −9.3%
Brand | PBM | 17.8% | 18.3% | 22.5% | 16.8% | 16.5% | 19.3%
Brand | Total | 100% | 100% | 100% | 100% | 100% | 100%
Brand | Sample Size ^[c]^ | 222 | 703 | 107 | 818 | 477 | 448
Generic | Manufacturer | 22.0% | 20.4% | ^[d]^ | 21.1% | 23.2% | 19.1%
Generic | Wholesaler | 16.2% | 12.4% | ^[d]^ | 14.1% | 12.1% | 16.0%
Generic | Pharmacy | 18.2% | 20.3% | ^[d]^ | 19.4% | 19.3% | 19.4%
Generic | PBM | 43.7% | 46.9% | ^[d]^ | 45.5% | 45.4% | 45.5%
Generic | Total | 100% | 100% | ^[d]^ | 100% | 100% | 100%
Generic | Sample Size ^[c]^ | 2,949 | 7,824 | 0 | 10,773 | 6,594 | 4,179
All Drugs | Manufacturer | 59.0%
All Drugs | Wholesaler | 10.0%
All Drugs | Pharmacy | 5.2%
All Drugs | PBM | 25.8%
All Drugs | Total | 100%
All Drugs | Sample Size ^[c]^ | 11,698

[a] Table presents weighted population estimates. Values may not add to 100% due to rounding.

[b] “Long” tenure refers to having more than 13 years or more than 9 years on the market for biologics and smallmolecules, respectively.

[c] Sample size refers to the number of unique observations of drugs (i.e., month and 11-digit NDC).

[d] Cannot be estimated because the sample did not contain any biosimilar drugs.