# APPENDIX B DETAILED METHODOLOGY

In this section, we describe elements of the methodology in greater detail.

## B.1 Merging Data Sources and Exclusions from Sample

For this analysis, we combined drug-level information from the following datasets:

▪ CMS State Drug Utilization Data (SDUD) reports utilization and spending by state Medicaid agencies.
▪ CMS NADAC contains national estimates of pharmacies’ acquisition costs.
▪ IQVIA NSP provides WACs, sales to providers, and utilization by API mass.
▪ IQVIA PayerTrak reports national projections for prescriptions filled as well as copays.
▪ SSR Health tracks manufacturers’ total price concessions (rebates, discounts, etc.).
▪ VA FSS price lists contains Big Four prices, which we used to estimate wholesaler discounts on generic drugs.
▪ CMS FUL contains maximum allowable Medicaid reimbursements for multi-source drugs, which we used to estimate PBMs’ payments to pharmacies for generic drugs.
▪ FDA National Drug Code (NDC) Directory contains drug information including the strength of the API.

We used 11-digit NDC codes to merge CMS SDUD, CMS NADAC, IQVIA NSP, VA FSS, CMS FUL, and FDA’s NDC Directory. While IQVIA PayerTrak does not contain 11-digit NDC numbers, we were able to find exact matches to specific NDCs using the available fields (molecule, product name, formulation, strength, brand/generic status, USC3 designation, corporation, manufacturer, and product launch date). We used SSR Health data on gross-to-net discount rates in all markets, Medicaid markets, and non-Medicaid markets. SSR Health identifies these discounts at the level of brand name. Accordingly, we matched products’ brand names in SSR Health to their proprietary name in the NDC Directory and applied the gross-to-net discount rates to all 11-digit NDCs associated with the given brand name.

In all cases, we matched datasets not only by drug, but also by time period. When datasets reported metrics by month, we aggregated monthly statistics into quarterly statistics. For IQVIA NSP, this involved taking a weighted average WAC, which we weighted by number of packages sold. For IQVIA PayerTrak, we used the projected number of national prescriptions (TRx) to weight the average copays for insured beneficiaries over time and across states and payer types. For NADAC, which is published every two weeks, we took an unweighted average of the available prices published within a quarter. Because the NADAC survey operates on a lag, we adjusted the effective price date based on the survey publication date using the procedure modeled by 46Brooklyn (46Brooklyn, n.d.).^40^

When selecting the final sample, the following exclusions were made:

▪ In SDUD, we excluded a drug’s observation at a given quarter only if both the FFS total reimbursement and MCO total reimbursement were missing. Otherwise, we used the non-missing value—or if both values were non-missing, we summed the non-missing reimbursements.
▪ We excluded drugs for which IQVIA data on total API sold (in kg or IU) was not available.
▪ For tractability when converting between price per package, price per unit, and price per API, we excluded drugs with multiple APIs.
▪ To facilitate conversion between package price, unit price, and API price, we excluded drugs that had inconsistent API strengths in different datasets or that presented a strength as a range rather than a definite value.
▪ We excluded observations of the WAC that were associated with a repackaged version of the drug (which constituted less than two percent of the identified retail drugs in IQVIA NSP) but retained WACs associated with the original package.
▪ We excluded drugs if, within a single month, the WAC or package information was not consistent across the retail observations.

In addition, we excluded specific drug products (collectively making up eight 11-digit NDCs) based on a manual review of outliers:

▪ We excluded VTAMA, which only had data for Q4 2022, because its SDUD reimbursement price was almost exactly double its WAC. The WAC was independently verified, suggesting that the SDUD price was likely reported in a different unit amount that could not be discerned.
▪ Similarly, we excluded Mounjaro and Asmanex Twisthaler due to inconsistencies across datasets, suggesting that prices were being reported with different units that could not be discerned. For example, for Asmanex Twisthaler, the SDUD reimbursement price per unit was three times the WAC per package.

## B.2 Converting Between Packages, Units, and API

The datasets expressed prices in different terms. WACs in IQVIA were typically in dollars per package, while NADAC, FUL, and SDUD were expressed in prices per unit (i.e., $ per mL of package contents, $ per gram of package contents, or $ per each/pill). To convert from WACs per package to WACs per unit of package contents, we divided the listed WAC by the quantity in one package and by the size of one package (if relevant). To convert from WAC per unit to WAC per amount of API,^41^ we identified the correct relationship between pack size, pack quantity, and API strength (and/or concentration) for each combination of formulation and pricing unit (either gram, mL, or each/pill according to NADAC), and we developed a unit-to-API price conversion for each drug group. We applied the same package-to-unit conversion for all price metrics given as prices per package, and the same unit-to-API conversion to all price metrics.

## B.3 Estimating Wholesalers’ Discounts Off WAC for Generic Drugs

To estimate the net price at which wholesalers acquire generic drugs, we used Big Four prices published by the VA in their FSS price list. We downloaded 23 historic FSS price lists published between January 1, 2020, and August 15, 2023. Each price list had a different “as of” date indicating when prices were updated. We selected the Big Four prices with contract periods that were active during the “as of” date and merged the resulting Big Four list with the IQVIA NSP retail drug dataset based on the 11-digit NDC, month, and year. We filtered the merged dataset to only contain generic retail drugs and calculated each drug’s WAC-to-Big Four discount rate.^42^ Instead of computing a single mean discount rate for all generics, we binned generic drugs into five groups based on their WAC price per unit. We found that quintiles of the WAC price per unit were the best predictors of the WAC-to-Big Four discount rate that a wholesaler would receive for a generic drug. We calculated these discounts in each year for each of the five generic drug groups, yielding five average wholesaler discount rates off WAC per year (Table B - 1).

Table B - 1 Mean WAC-to-Big Four Discount, based on Quintiles of WAC per Unit

WAC Quintile | Range of WAC per Unit | WAC-to-Big Four Discount
WAC Quintile | Range of WAC per Unit | 2020 | 2021 | 2022 | 2023
1 | ≤$0.17 | 66.1% | 64.9% | 69.0% | 64.0%
2 | >$0.17 to ≤$0.44 | 71.1% | 72.3% | 74.8% | 59.5%
3 | >$0.44 to ≤$1.18 | 73.2% | 76.2% | 75.3% | 65.4%
4 | >$1.18 to ≤$4.69 | 75.2% | 78.3% | 80.8% | 84.4%
5 | >$4.69 | 71.5% | 72.3% | 70.9% | 61.8%

While the mean discount generally increases with WAC per unit, there is substantial noise in the data. Figure B - 1 shows the boxplot for each generic drug group when aggregated across the full time series. Each shaded point represents a different contract for a specific drug at a given time period from 2020 through August 2023.

Relatedly, four of the five generic groups experienced a substantial decline in the second half of 2022 compared to previous time periods, as Figure B - 2 shows.

Figure B - 1 WAC-to-Big Four Discount for Generic Drug Groups Defined by WAC per Unit

Figure B - 1 is a box plot showing the mean wholesale acquisition cost to big four discount by quintile across all time periods. It shows that for each quintile, there is significant variation in the wholesale acquisition cost to big four discount over time.

Figure B - 2 Trends in WAC-to-Big Four Discounts over Time, by Generic Group

Figure B - 2 is a line graph showing the mean wholesale acquisition cost to big four discount by quintile over time. The graph shows that starting in the second half of 2022, the discount for the fourth quintile, which is for wholesale acquisition costs between $1.18 and $4.69, increased from 80.8 percent to 84.4 percent, and the discount for the other quintiles decreased.

## B.4 Separating Manufacturer Rebates from Other Price Concessions

For brand drugs, a central estimate in our methodology is the total rebate a manufacturer pays to the PBM for a given drug. Ultimately, we use this estimate to calculate multiple sources of PBMs’ margins from brand drugs.

To estimate rebates that manufacturers pay PBMs, we used data from SSR Health on gross-to-net discounts. These gross-to-net discounts capture all manufacturer price concessions, including rebates and administrative fees paid to the PBM, rebates paid to the Medicaid Drug Rebate Program, and discounts provided to the wholesaler, among other sources. In this section, we derive a formula for separating the manufacturer rebate (including administrative fees) from the other price concessions. We used this equation to estimate the rebates as a fraction of the WAC.

SSR Health provides three gross-to-net discount rates: the average discount on all units sold g_t_, the average discount on Medicaid units g_M_, and the average discount on non-Medicaid units g_n_. The Medicaid discount g_M_ accounts for (a) the statutory rebate equal to 23.1 percent of AMP for brand drugs and 13 percent of AMP for generic drugs and (b) the inflation-based rebate when a drug’s AMP increases faster than the rate of inflation. However, the Medicaid discount g_M_ does not account for discounts the manufacturer gives the wholesaler, and it does not account for the best price provision.

The gross profit from all units R_t_ can be divided up into the gross profits on non-Medicaid units R_n_ and the gross profits on Medicaid units R_M_:

R_t_ = R_n_ + R_M_ Equation B-1: R subscript t end subscript equals R subscript n end subscript plus R subscript uppercase M end subscript. (B – 1)

Based on the SSR Health gross-to-net definition, we estimate each of the gross profits R_t_, R_n_, and R_M_ as the difference between expenditures at the WAC price and expenditures at the net price. For example, the total gross profit is:

R_t_ = (u_tot_) ( WAC ) − (u_tot_) ( WAC ) g_t_ Equation B-2: R subscript t end subscript equals open parentheses u subscript tot end subscript close parentheses times open parentheses WAC close parentheses minus open parentheses u subscript tot end subscript close parentheses times open parentheses WAC close parentheses times open parentheses g subscript t end subscript close parentheses. (B – 2)

where the total number of units u_tot_ is equal to the number of non-Medicaid units sold u_n_ plus the number of Medicaid units sold u_M_. Simplifying Eq. B-2 yields:

R_t_ = (1 − g_t_) (u_n_ + u_M_) ( WAC ) Equation B-3: R subscript t end subscript equals open parentheses 1 minus g subscript t end subscript close parentheses times open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses times open parentheses WAC close parentheses. (B – 3)

Applying this to each term in Eq. B-1 gives the following:

(1 − g_t_) (u_n_ + u_M_) ( WAC ) = (1 − g_n_) (u_n_) ( WAC ) + (1 − g_m_) (u_M_) ( WAC ) Equation B-4: open parentheses 1 minus g subscript t end subscript close parentheses times open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses times open parentheses WAC close parentheses equals open parentheses 1 minus g subscript n end subscript close parentheses times open parentheses u subscript n end subscript close parentheses times open parentheses WAC close parentheses plus open parentheses 1 minus g subscript lowercase m end subscript close parentheses times open parentheses u subscript uppercase M end subscript close parentheses times open parentheses WAC close parentheses. (B – 4)

Eq. B-4 can be rearranged to give the ratio of Medicaid to non-Medicaid units in terms of the three gross-to-net discounts:

(u_M_)/(u_n_) = (g_t_ − g_n_)/(g_M_ − g_t_) Equation B-5: begin fraction open parentheses u subscript uppercase M end subscript close parentheses over open parentheses u subscript n end subscript close parentheses end fraction equals begin fraction open parentheses g subscript t end subscript minus g subscript n end subscript close parentheses over open parentheses g subscript uppercase M end subscript minus g subscript t end subscript close parentheses end fraction. (B – 5)

Eq. B-5 is derived from SSR Health’s definitions of gross-to-net discounts which, in the case of the Medicaid units, does not account for prices concessions beyond the statutory Medicaid rebates. Thus, we can modify Eq. B-1 to re-allocate total gross profits R_t_ in a way that accounts for other concessions that may apply to Medicaid units. Doing so maintains the same total gross profits R_t_ but attributes a larger portion to Medicaid units and a smaller portion to non-Medicaid units. We use R_n_^*^ and R_M_^*^ for the updated estimates of gross profits in the non-Medicaid and Medicaid markets, respectively, where reallocating some price concessions to Medicaid units leads to a larger estimate of gross profits in Medicaid markets R_M_^*^ > R_M_ and a smaller estimate of gross profits in non-Medicaid markets R_n_^*^ > R_n_ . However, this only constitutes a re-allocation of the total gross profits R_t_, which remain the same:

R_t_ = R_n_^*^ + R_M_^*^ Equation B-6: R subscript t equals R superscript asterisk end superscript subscript n end subscript plus R superscript asterisk end superscript subscript uppercase M end subscript. (B – 6)

The updated Medicaid gross profits R_M_^*^ now account for the statutory Medicaid rebate (i.e., SSR Health’s Medicaid gross-to-net discount g_M_) as well as rebates that the PBM may receive on Medicaid units d_M_^( reb )^ and discounts the wholesaler may receive d_M_^( oth )^ :

R_t_ = R_n_^*^ + ( WAC ) (u_M_) (1 − g_M_ − d_M_^( reb )^ − d_M_^( oth )^) Equation B-7: R subscript t end subscript equals R superscript asterisk end superscript subscript n end subscript plus open parentheses WAC close parentheses times open parentheses u subscript uppercase M end subscript close parentheses times open parentheses 1 minus g subscript uppercase M end subscript minus d superscript open parentheses reb close parentheses end superscript subscript uppercase M end subscript minus d superscript open parentheses oth close parentheses end superscript subscript uppercase M end subscript close parentheses. (B – 7)

Similarly, non-Medicaid gross profits R_n_ can also be broken into its constituent parts. In our model, we account for two main components, manufacturer rebates d_n_^( reb )^ and wholesaler discounts d_n_^( oth )^ .

R_t_ = ( WAC ) (u_n_) (1 − d_n_^( reb )^ − d_n_^( oth )^) + ( WAC ) (u_M_) (1 − g_M_ − d_M_^( reb )^ − d_M_^( oth )^) Equation B-8: R subscript t end subscript equals open parentheses WAC close parentheses times open parentheses u subscript n end subscript close parentheses times open parentheses 1 minus d superscript open parentheses reb close parentheses end superscript subscript n end subscript minus d superscript open parentheses oth close parentheses end superscript subscript n end subscript close parentheses plus open parentheses WAC close parentheses times open parentheses u subscript uppercase M end subscript close parentheses times open parentheses 1 minus g subscript uppercase M end subscript minus d superscript open parentheses reb close parentheses end superscript subscript uppercase M end subscript minus d superscript open parentheses oth close parentheses end superscript subscript uppercase M end subscript close parentheses. (B – 8)

We make the simplifying assumption that PBM rebates on brand drugs are the same for Medicaid and non-Medicaid units (d_n_^( reb )^ = d_M_^( reb )^ ≡ d^( reb )^) , and likewise that wholesaler discounts are the same for Medicaid and non-Medicaid units (d_n_^( oth )^ = d_M_^( oth )^ ≡ d^( oth )^) . Then, Eq. B-8 rearranges to:

(R_t_)/(WAC) = u_n_ (1 − d^( oth )^) + u_M_ (1 − g_M_ − d^( oth )^) − (u_n_ + u_M_) d^( reb )^ Equation B-9: begin fraction open parentheses R subscript t end subscript close parentheses over open parentheses WAC close parentheses end fraction equals u subscript n end subscript times open parentheses 1 minus d superscript open parentheses oth close parentheses end superscript close parentheses plus u subscript uppercase M end subscript times open parentheses 1 minus g subscript uppercase M end subscript minus d superscript open parentheses oth close parentheses end superscript close parentheses minus open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses times d superscript open parentheses reb close parentheses end superscript. (B – 9)

d^( reb )^ = (u_n_)/(u_n_ + u_M_) (1 − d^( oth )^) + (u_M_)/(u_n_ + u_M_) (1 − g_M_ − d^( oth )^) − (R_t_)/(( WAC ) (u_n_ + u_M_)) Equation B-10: d superscript open parentheses reb close parentheses end superscript equals begin fraction open parentheses u subscript n end subscript close parentheses over open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses end fraction times open parentheses 1 minus d superscript open parentheses oth close parentheses end superscript close parentheses plus begin fraction open parentheses u subscript uppercase M end subscript close parentheses over open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses end fraction times open parentheses 1 minus g subscript uppercase M end subscript minus d superscript open parentheses oth close parentheses end superscript close parentheses minus begin fraction open parentheses R subscript t end subscript close parentheses over open parentheses open parentheses WAC close parentheses times open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses close parentheses end fraction. (B – 10)

However, the expression (R_t_)/(( WAC ) (u_n_ + u_M_)) is equal to SSR Health’s definition of 1 — (total gross to-net discount rate). Thus:

d^( reb )^ = (u_n_)/(u_n_ + u_M_) (1 − d^( oth )^) + (u_M_)/(u_n_ + u_M_) (1 − g_M_ − d^( oth )^) − (1 − g_t_) Equation B-11: d superscript open parentheses reb close parentheses end superscript equals begin fraction open parentheses u subscript n end subscript close parentheses over open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses end fraction times open parentheses 1 minus d superscript open parentheses oth close parentheses end superscript close parentheses plus begin fraction open parentheses u subscript uppercase M end subscript close parentheses over open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses end fraction times open parentheses 1 minus g subscript uppercase M end subscript minus d superscript open parentheses oth close parentheses end superscript close parentheses minus open parentheses 1 minus g subscript t end subscript close parentheses. (B – 11)

From Eq. B-5, it can be shown that:

(u_M_)/(u_n_ + u_M_) = (g_t_ − g_n_)/(g_M_ − g_n_) and (u_n_)/(u_M_ + u_n_) = (g_M_ − g_t_)/(g_M_ − g_n_) Equation B-12: begin fraction open parentheses u subscript uppercase M end subscript close parentheses over open parentheses u subscript n end subscript plus u subscript uppercase M end subscript close parentheses end fraction equals begin fraction open parentheses g subscript t end subscript minus g subscript n end subscript close parentheses over open parentheses g subscript uppercase M end subscript minus g subscript n end subscript close parentheses end fraction, and begin fraction open parentheses u subscript n end subscript close parentheses over open parentheses u subscript uppercase M end subscript plus u subscript n end subscript close parentheses end fraction equals begin fraction open parentheses g subscript uppercase M end subscript minus g subscript t end subscript close parentheses over open parentheses g subscript uppercase M end subscript minus g subscript n end subscript close parentheses end fraction. (B – 12)

Combining Eq. B-11 and Eq. B-12 gives:

d^( reb )^ = (g_M_ − g_t_)/(g_M_ − g_n_) (1 − d^( oth )^) + (g_t_ − g_n_)/(g_M_ − g_n_) (1 − g_M_ − d^( oth )^) − (1 − g_t_) Equation B-13: d superscript open parentheses reb close parentheses end superscript equals begin fraction open parentheses g subscript uppercase M end subscript minus g subscript t end subscript close parentheses over open parentheses g subscript uppercase M end subscript minus g subscript n end subscript close parentheses end fraction times open parentheses 1 minus d superscript open parentheses oth close parentheses end superscript close parentheses plus begin fraction open parentheses g subscript t end subscript minus g subscript n end subscript close parentheses over open parentheses g subscript uppercase M end subscript minus g subscript n end subscript close parentheses end fraction times open parentheses 1 minus g subscript uppercase M end subscript minus d superscript open parentheses oth close parentheses end superscript close parentheses minus open parentheses 1 minus g subscript t end subscript close parentheses. (B – 13)

We used Eq. B-13 to calculate d^(reb)^, the fraction of the WAC equal to the manufacturer rebate. We performed this calculation for each drug with SSR Health data, effectively separating out the rebate from wholesaler discounts and statutory Medicaid rebates. As stated in Section 3.3.1, we assume wholesalers receive a discount off WAC d^(oth)^ of 9 percent. In a small number of cases, we set the rebate to 0 percent because Eq. B-13 yielded a negative rebate. (For example, this could arise if the total gross-to-net discount was less than the assumed wholesaler discount of 9 percent.)

As described previously, we estimated that the PBM retains 0.4 percent of the manufacturer rebate. While the total rebate itself is quite large, the amount of the PBM retains is relatively small compared to other sources of PBM margins, and this is due to PBMs passing along a large portion of the manufacturer rebate to the third-party payer.

One limitation of Eq. B-13 is that it does not account for the best-price provision of the Medicaid rebate. However, this effect is likely relatively small. A recent study estimated that taking the best-price provision into account only led to an overall 2-3 percent reduction of AMP across 18 top-selling brand drugs between 2015 and 2019 (Clemans-Cope et al. 2023).

## B.5 Estimating Pharmacy DIR

This section describes how we used the Iowa PBM Annual Reports(Iowa Insurance Division, 2020-2023) to estimate total DIR retained by PBMs, a portion of which we allocate to pharmacy DIR. In the Iowa PBM Annual Reports, each PBM discloses the total DIR they collect. According to the Iowa Code (Iowa Code 2023, Section 510B.1 (22, 3) , 2023):

[PBMs must report] all discounts and other negotiated price concessions paid directly or indirectly by a pharmaceutical manufacturer or other entity, other than a covered person, in the prescription drug supply chain to a pharmacy benefits manager, and which may be based on any of the following:

a. A pharmaceutical manufacturer’s list price for a prescription drug.
b. Utilization.
c. To maintain a net price for a prescription drug for a specified period of time for the pharmacy benefits manager in the event the pharmaceutical manufacturer’s list price increases.
d. Reasonable estimates of the volume of a prescribed drug that will be dispensed by a pharmacy to covered persons.

The Iowa code further stipulates that this DIR (which the code refers to as “rebate,” using a broad definition) does not include administrative fees that the manufacturer pays to the PBM; such administrative fees are reported separately in the Annual Reports.

In addition to the total DIR PBMs collect (excluding manufacturer administrative fees), the Iowa Annual Reports also show the amount of total DIR that the PBM retains. We aggregated these amounts for the years 2021 and 2022, which are presented in the reports from 2022 and 2023, respectively. We found that, on average PBMs retain 12.4 percent of the total DIR they collect from pharmacies and manufacturers:

(manf. rebate + DIR_ph_) ( 0.124 ) = total DIR retained Equation B-14: open parentheses manf.rebate plus DIR subscript ph end subscript close parentheses times open parentheses 0.124 close parentheses equals total DIR retained. (B – 14)

where DIR_ph_ is the pharmacy DIR that the PBM collects. However, based on the 2019 GAO report, we assume only 0.4 percent of manufacturer rebate is retained.^43^ We further assume that all of the collected pharmacy DIR is retained by the PBM.^44^ Thus:

DIR_ph_ + ( 0.004 ) ( manf. rebate ) = total DIR retained Equation B-15: DIR subscript ph end subscript plus open parentheses 0.004 close parentheses times open parentheses manf.rebate close parentheses equals total DIR retained. (B – 15)

Setting Eq. B-14 equal to Eq. B-15 yields:

(rebate + DIR_ph_) ( 0.124 ) = DIR_ph_ + ( 0.004 ) ( rebate ) Equation B-16: open parentheses rebate plus DIR subscript ph end subscript close parentheses times open parentheses 0.124 close parentheses equals DIR subscript ph end subscript plus open parentheses 0.004 close parentheses times opne parentheses rebate close parentheses. (B – 16)

Rearranging Eq. B-16 gives an expression for the pharmacy DIR that the PBM collects.

DIR_ph_ = ((0.124 − 0.004)/(1 − 0.124)) rebate = ( 0.137 ) ( rebate ) Equation B-17: DIR subscript ph end subscript equals begin fraction open parentheses 0.124 minus 0.004 close parentheses over open parentheses 1 minus 0.124 close parentheses end fraction times rebate equals open parentheses 0.137 close parentheses times open parentheses rebate close parentheses. (B – 17)

Accordingly, we assume that 13.7 percent of the computed rebate is pharmacy DIR that the PBM collects and retains in its entirety. While some DIR may be passed through to the payer (e.g., as in the case of Medicare Part D), much less is known about performance-based DIR, retrospective “true-up” fees (which often occur at the level of pharmacy networks), network participation fees, etc. However, one expert we spoke with speculated that PBMs may retain all or nearly all of these “non-traditional” forms of DIR, which likely contribute substantially to PBMs margins. Any pharmacy DIR that is passed through to the payer is not accounted in our model and would constitute an additional flow from PBM to payer. This would tend to decrease pharmacies’ margins while leaving PBMs’ margins unchanged.

The methodology above is applicable for brand drugs whose rebates we calculated. For generic drugs, we assumed pharmacy DIR was 8 percent of the difference between pharmacies’ sales price and acquisition cost, based on a 2019 analysis by Drug Channels Institute (Fein, 2019), as discussed in more detail previously.

40 In this procedure, each possible survey publication date is mapped to the month whose data would likely be captured by a survey published on that date. In general, the first possible publication date mapped to a given month is the second to last Wednesday of the following month, with the last date being the Tuesday before the second to last Wednesday of the month following that. In the case when a month has 31 days and ends on a Wednesday, the third to last Wednesday is used instead of the second to last Wednesday as the first publication date corresponding to data from the previous month.

41 We expressed API amounts using mg of mass for nearly all drugs, and mega-units of activity for insulin.

42 We removed matches for which (a) the difference in Big Four and WAC prices was more than 100 percent, (b) the Big Four price was greater than the WAC, or (c) the drug (11-digit NDC) had multiple Big Four prices from the same vendor in the same month.

43 Iowa statute prohibits at least some forms of pharmacy DIR that we quantify in this report. Combining the Iowa PBM Annual Reports with the GAO report therefore carries an assumption that the fraction of total DIR that PBMs retain is the same in Iowa as in the United States overall, though there may be variation by state in the fraction of total DIR derived from pharmacy DIR versus other sources (e.g., manufacturer rebates).

44 Here, we define pharmacy DIR broadly to capture all sources of DIR that a PBM collects from the pharmacy. This may include retrospective concessions to “true up” the PBMs’ actual reimbursements with contract rates, penalties assessed by the PBM based on performance metrics, “pay-to-play” network participation fees, etc.