# APPENDIX A COMPENDIUM OF STATE STATUTES ADDRESSING PBM ISSUES

Definitions of Types of Legislation and state tables adapted from:

- National Conference of State Legislatures (2022) State Policy Options and Pharmacy Benefit Managers (PBMs). https://www.ncsl.org/health/state-policy-options-and-pharmacy-benefit-managers.
- Statutes enacted after March 23, 2022, are from: National Conference of State Legislatures, (n.d.) Prescription Drug State Bill Tracking Database, 2015-Present. Updated 09/11/2023. https://www.ncsl.org/health/prescription-drug-state-bill-tracking-database-2015-present

## Types of Legislation

### Cost disclosure/Anti-gag clause

The terms of PBM contracts with pharmacies and manufacturers are often proprietary and unknown to consumers and some purchasers, like employers. The terms can include a “gag clause,” which restricts pharmacists from informing consumers of lower cost options, such as if a consumer purchases a prescription out of pocket rather than using the drug benefit through their insurance plan. Some states have banned the use of these gag clauses.

### Giving PBMs Fiduciary Status

While some states impose fiduciary responsibilities^39^ on PBMs, others require PBMs to exercise good faith and fair dealing while performing their contractual duties.

### Controlling Maximum Allowable Cost (MAC) Lists

PBMs will establish an upper limit or maximum amount they will reimburse a pharmacy for generic and multi-source drugs. These maximum allowable costs (MAC) lists may consist of thousands of products. Some states regulate how often MAC lists are updated, and/or establish a way pharmacies can appeal when they dispute reimbursements.

### Assuring Network Adequacy

Pharmacy network adequacy is often defined by the distance between a patient’s residence and an accessible pharmacy. State laws generally set adequacy and eligibility standards for network participation. For example, Oklahoma’s statute, 36 OK Stat § 36-6961 (2021) (https://law.justia.com/citations.html), states that, in urban service areas, at least 90 percent of a PBM’s covered individuals must live within two miles of a pharmacy in the PBM’s retail network. In suburban areas, 90 percent of covered individuals must live within 5 miles of a network pharmacy, and in rural service areas, 70 percent must live within 15 miles of a pharmacy in the PBM’s network. Oklahoma also prohibits PBMs from denying participation in their network to any pharmacy “willing to accept the terms and conditions that the PBM has established for other pharmacies” already in their network. Other state legislation under this heading assures patients the right to use a pharmacy of their choice without penalty.

### Anti-Patient Steering

Some PBMs require contracted health plan enrollees to visit their affiliated pharmacies, or pharmacies in which they have an ownership interest including retail, mail-order or specialty. Some states have made this unallowable.

### Pharmacy Auditing Standards/Appeals Process

PBMs audit pharmacies to detect fraud, waste, and abuse. Some state laws are intended to assure the fairness of these audits and provide pharmacies a process for appeal. State laws are intended to provide guidelines on when and how pharmacy audits are conducted by PBMs. Some states have made PBMs subject to audit by a state agency.

### Pharmacy Reimbursement/Clawbacks

Clawbacks occur when a health plan enrollee’s copayment exceeds the total cost of the drug to their insurer, and the PBM “claws back” some, or all, of the overpayment from the pharmacy. Some states have chosen to prohibit these types of retroactive payments and at least 22 states have enacted some form of anti-clawback legislation.

### Registration/Licensure

States may require PBMs to register or be licensed to conduct business, often through the state department of insurance or board of pharmacy.

### Regulatory Agency/Enforcement

Many states that require PBM registration or licensure also authorize a specific agency to promulgate and enforce rules and regulations via fines, civil penalties, or license revocation.

### Reporting/Transparency Requirements

Some states have implemented laws that require PBMs to disclose certain pricing and cost information such as data on rebates, payments and fees collected from drug manufacturers, insurers, and pharmacies. Frequently, these disclosures are limited to a specific state agency, which treats them as confidential business information.

### Anti-Spread Pricing

In a spread pricing model, the PBM keeps a portion of the amount, or spread, between what the health plan pays the PBM and the amount that the PBM reimburses the pharmacy for a beneficiary’s prescription. With a pass-through contract, the PBM passes through the amount charged by the pharmacy to the health insurer. Since no spread is collected, PBMs typically charge an administrative fee. Some states have banned spread pricing.

### Utilization Management Tools (e.g., Prior Authorization, Step-Therapy, Non-Medical Switching)

Utilization management tools are used by PBMs (on behalf of payers) to manage the costs of pharmaceutical and other treatments, often for non-medical reasons. “Prior authorization” requires providers to request approval from the PBM/insurer for a specific therapy before they can prescribe it. Step therapy requires a patient and their doctor to try specific treatments before switching to a more expensive or non-generic alternative. Non-medical switching occurs when a patient who is stable on one medicine is switched to another one for non-clinical reasons. Some states have legislated limits on the use of utilization management tools.

### Other

Some states have pursued other activities related to PBM reform not highlighted in the above categories. For instance, in a reverse auction PBMs compete for a state’s business and the lowest offer is awarded the contract. Other actions prohibit discriminatory practices against a pharmacy that participates in the federal 340B program.

Table A - 1 States with Statutes Addressing PBM-related Issues

Legislative Target | Number of States w/ Statute
Cost Disclosure/Anti-Gag Clause | 44
Fiduciary Status for PBM | 14
Maximum Allowable Cost Lists | 35
Network Adequacy | 28
Anti-Patient Steering | 14
Pharmacy Reimbursement/Anti-Claw Backs | 34
Pharmacy Auditing Standards/Appeals Process | 43
Registration Licensure | 43
Regulatory Agency/Enforcement | 43
Reporting/Transparency Requirements | 34
Anti-Spread Pricing | 16
Limits to Utilization Management Tools | 22
Other | 21

Source: National Conference of State Legislatures (2022, March 23)

39 “U.S. law and standards of professional conduct oblige fiduciaries to exercise a high standard of care, loyalty, and honesty in providing services to their clients and intermediaries. The fiduciary is required to prioritize the interests of the beneficiary over their own. Fiduciary duty is a serious obligation. If a fiduciary does not fulfill their duties, called a breach of fiduciary duty, the beneficiary could be entitled to damages” (Tretina, 2023). Fiduciary duties may vary depending on the nature and roles of the entities involved. However, the duties of honesty, loyalty, good faith, and the duty to disclose all information that could impact the beneficiary are apparently germane to the PBM/insurer/ patient relationship.