# ABBREVIATIONS

Abbreviation: Definition
AHIP: America’s Health Insurance Plans
AMP: Average Manufacturer Price
API: Active Pharmaceutical Ingredient
ASPE: Office of the Assistant Secretary of Planning and Evaluation
ATC: Anatomical Therapeutic Chemical
CAGR: Compound Annual Growth Rate
CHIP: Children’s Health Insurance Program
CMS: Centers for Medicare & Medicaid Services
DIR: Direct and Indirect Remuneration
FDA: Food and Drug Administration
FFS: Fee-for-Service
FSS: Federal Supply Schedule
FTC: Federal Trade Commission
FUL: Federal Upper Limit
GAO: Government Accountability Office
GPO: Group Purchasing Organization
HHS: U.S. Department of Health and Human Services
MAC: Maximum Allowable Cost
MCO: Managed Care Organization
MEPA: Modernizing and Ensuring PBM Accountability Act
NADAC: National Average Drug Acquisition Cost
NARP: National Average Retail Price
NCPA: National Community Pharmacists Association
NDC: National Drug Code
NSP: IQVIA National Sales Perspectives
PBM: Pharmacy Benefit Manager
PCMA: Pharmaceutical Care Management Association
SDP: Office of Science and Data Policy
SDUD: State Drug Utilization Data
SEC: Securities and Exchange Commission
VA: U.S. Department of Veterans Affairs
WAC: Wholesale Acquisition Cost