# REFERENCES

Anderson, L. A., 2023. National Drug Codes Explained. [Online] Available at: https://www.drugs.com/ndc.html [Accessed 2024].
Bansal, R., De Backer, R. & Ranade, V., 2018. What’s behind the pharmaceutical sector’s M&A push, [Online]: MicKinsey & Company.
Bena, J. & Li, K., 2014. Corporate Innovations and Mergers and Acquisitions. Journal of Finance, 69(5), pp. 1923–1960.
Bernauer, T., Kaetzler, R., Parekh, R. & Rudnicki, J., 2024. Life sciences M&A shows new signs of life, [Online]: McKinsey & Company. Available at: https://www.mckinsey.com/capabilities/m-and-a/our-insights/life-sciences-m-and-a-shows-new-signs-of-life.
Bonaime, A. & Wang, Y., 2024. Mergers, Product Prices, and Innovation: Evidence from the Pharmaceutical Industry. The Journal of Finance, 79(3), pp. 2195–2236.
Carey, T., 2023. ‘The Top Line’: How Pfizer became the first in Big Pharma history to break $100B in sales, [Online]: Fierce Pharma. Available at: www.fiercepharma.com/pharma/top-line-how-pfizer-became-first-company-industry-history-100-billion-dollars-sales-plus.
Center for Research in Security Prices, 2023. CRSP/Compustat Merged Database Guide for SAS, ASCII & R, Chicago https://www.crsp.org/wp-content/uploads/guides/CRSP_Compustat_Merged_Database_Guide_for_SAS_ASCII_R.pdf: s.n.
Chintan, D., Kesselheim, A. S., Fox, E. R. & Qiu, P., 2017. High Generic Drug Prices and Market Competition: A Retrospective Cohort Study. Annals of Internal Medicine, 167(3).
CVS Health, 2023. CVS Health Launches Cordavis. [Online] Available at: https://www.prnewswire.com/news-releases/cvs-health-launches-cordavis-301908281.html [Accessed 2024].
DealForma, 2024. [Online] Available at: https://dealforma.com/ [Accessed 9 May 2024].
FactSet, 2024. [Online] Available at: https://www.factset.com/ [Accessed 2024].
FactSet, 2024. At a Glance: FactSet Fundamentals Datafeed. [Online] Available at: https://insight.factset.com/resources/at-a-glance-factset-fundamental-datafeed [Accessed 2024].
Fein, A., 2024. Drug Channels News Roundup, June 2024: Cordavis Humira Update, OptumRx’s New Biosim Biz, Generic Drugs’ Wild Ride, IRA Predictions, and Dr. G on Med School. [Online] Available at: https://www.drugchannels.net/2024/06/drug-channels-news-roundup-june-2024.html [Accessed 2024].
Feldman, R., Fulton, B., Godwin, J. & Scheffler, R., 2022. Challenges with Defining Pharmaceutical Markets and Potential Remedies to Screen for Industry Consolidation. J Health Polit Policy Law, 47(5), pp. 583–607.35576314
Feng, J., Hwang, T., Liu, Y. & Maini, L., 2023. Mergers that Matter: The Impact of M&A Activity in Prescription Drug Market. Working Paper, 27 July.
Gagnon, M. A., 2012. Drug Shortages: Searching for a Cure. Healthcare Policy, 7(4), pp. 10–17.
Gagnon, M. A. & Volesky, K. D., 2017. Merger mania: mergers and acquisitions in the generic drug sector from 1995 to 2016. Globalization and Health, 13(62).
Global Data, 2024. Pharma M&A Deals Q1 2024 – Top Themes – Thematic Intelligence, s.l.: s.n.
Guardado, J., 2024. Competition in PBM Markets and Vertical Integration of Insurers with PBMs: 2024 Update. [Online] Available at: https://www.ama-assn.org/system/files/prp-pbm-shares-hhi-2024.pdf
Gupta, R., Shah, N. & Ross, J., 2019. Generic Drugs in the United States: Policies to Address Pricing and Competition. Clinical Pharmacology and Therapeutics, 105(2), pp. 329–337. doi: 10.1002/cpt.1314.30471089
Hammoudeh, M. & Nain, A., 2024. Seeking Efficiency or Price Gouging? Evidence from Pharmaceutical Mergers, s.l.: University of Iowa.
Haninger, K., Jessup, A. & Koehler, K., 2011. Economic Analysis of the Causes of Drug Shortages, s.l.: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation (ASPE).
HHS ASPR and ARMI, 2022. Essential Medicines Supply Chain and Manufacturing Resilience Assessment, s.l.: s.n.
Hyman, Phelps & McNamara PC, 2024. The Orange Book Archives. [Online] Available at: https://www.thefdalawblog.com/orange-book-archives/
International Monteary Fund, 2024. Exchange Rate Archives by Month. [Online] Available at: https://www.imf.org/external/np/fin/data/param_rms_mth.aspx [Accessed 10 July 2024].
Internet Archive, 2024. [Online] Available at: https://archive.org/
Jaspen, B., 2020. Blue Cross Insurers To Create Their Own Drug Company Amid Price Fight. [Online] Available at: https://www.forbes.com/sites/brucejapsen/2020/01/23/blue-cross-insurers-to-create-their-own-drug-company-amid-price-fight/ [Accessed 2024].
Joyce, G., 2023. Blame Capitalism? Why Hundreds of Decades-Old Yet Vital Drugs Are Nearly Impossible to Find, s.l.: USC Schaeffer.
National Economic Council, National Security Council, 2024. 2021–2024 Quadrennial Supply Chain Review, Washington, D.C.: The White House.
Richman, B. D., Mitchell, W., Vidal, E. & Schulman, K. A., 2017. Pharmaceutical M&A Activity: Effects on Prices, Innovation, and Competition. Rotman School of Management Working Paper No. 2977703, Loyola University Chicago Law, 30 May.Volume 48.
Schutz, S., 2023. Mergers, Prices, and Innovation: Lessons from the Pharmaceutical Industry, s.l.: SSRN.
Schweitzer, S. O., 2013. How the US Food and Drug Administration can solve the prescription drug shortage problem. Am J Public Health, Mau, 103(5), pp. e10–4.
Standard & Poor’s, 2002. COMPUSTAT® (Global) Data Guide, s.l.: The McGraw-Hill Companies, Inc.
Standard & Poor’s, 2003. Standard & Poor’s Compustat® User’s Guide, s.l.: The McGraw-Hill Companies, Inc.
Statistics Solutions, 2025. Homoscedasticity. [Online] Available at: https://www.statisticssolutions.com/free-resources/directory-of-statistical-analyses/homoscedasticity/
Teva Pharmaceuticals, 2015. Teva to Acquire Allergan Generics for $40.5 Billion Creating a Transformative Generics and Specialty Company Well Positioned to Win in Global Healthcare. [Online] Available at: https://www.tevapharm.com/news-and-media/latest-news/teva-to-acquire-allergan-generics-for-$40.5-billion-creating-a-transformative-generics-and-specialty-comp/ [Accessed 24 June 2024].
The Multi-Stakeholder Steering Committee On Drug Shortages In Canada, 2017. Preventing Drug Shortages: Identifying Risks and Strategies to Address Manufacturing-Related Drug Shortages in Canada, s.l.: s.n.
The White House, 2021. Building Resilient Supply Chains, Revitalizing American Manufacturing, and Fostering Broad-Based Growth, s.l.: s.n.
U.S. Bureau of Labor Statistics, 2024. Consumer Price Index for All Urban Consumers: Medical Care in U.S. City Average. [Online] Available at: https://fred.stlouisfed.org/series/CPIMEDSL
U.S. Department of Health and Human Services, 2024. Policy Considerations to Prevent Drug Shortages and Mitigate Supply Chain Vulnerabilities in the United States, s.l.: s.n.
U.S. Department of Justice and the Federal Trade Commission, 2023. Merger Guidelines, s.l.: s.n.
U.S. Department of Justice, 2024. Herfindahl-Hirschman Index. [Online] Available at: https://www.justice.gov/atr/herfindahl-hirschman-index
U.S. Federal Trade Commission, 2022. Public Workshop on the Future of Pharmaceuticals: Examining the Analysis of Pharmaceutical Mergers. Washington, DC, U.S. Federal Trade Commission..
U.S. Federal Trade Commission, 2024. Pharmacy Benefit Managers: The Powerful Middlemen Inflating Drug Costs and Squeezing Main Street Pharmacies, s.l.: s.n.
U.S. Food & Drug Administration, 2011. A Review of FDA’s Approach to Medical Product Shortages, s.l.: s.n.
U.S. Food & Drug Administration, 2019. Center for Biologic Evaluation and Research List of Licensed Biological Products with (1) Reference Product Exclusivity and (2) Biosimilarity or Interchangeability Evaluations to Date. [Online] Available at: https://www.fda.gov/downloads/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApproved/ApprovalApplications/TherapeuticBiologicApplications/Biosimilars/UCM412398.pdf
U.S. Food & Drug Administration, 2019. Center for Drug Evaluation and Research List of Licensed Biological Products with (1) Reference Product Exclusivity and (2) Biosimilarity or Interchangeability Evaluations to Date. [Online] Available at: https://www.fda.gov/downloads/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApproved/ApprovalApplications/TherapeuticBiologicApplications/Biosimilars/UCM560162.pdf
U.S. Food & Drug Administration, 2020. Drug and Biologic Essential Medicines, Medical Countermeasures, and Critical Inputs for the List Described in Section 3(c) of the Executive Order 13944. [Online] Available at: https://www.fda.gov/media/143406/download?attachment
U.S. Food & Drug Administration, 2020. FDA Publishes List of Essential Medicines, Medical Countermeasures, Critical Inputs Required by Executive Order. [Online] Available at: https://www.fda.gov/news-events/press-announcements/fda-publishes-list-essential-medicines-medical-countermeasures-critical-inputs-required-executive
U.S. Food & Drug Administration, 2022. National Drug Code Directory. [Online] Available at: https://www.fda.gov/drugs/drug-approvals-and-databases/national-drug-code-directory [Accessed 2024].
U.S. Food & Drug Administration, 2023. Report to Congress Drug Shortages CY 2023, s.l.: s.n.
U.S. Food & Drug Administration, 2024. CBER-Regulated Products: Current Shortages. [Online] Available at: https://www.fda.gov/vaccines-blood-biologics/safety-availability-biologics/cber-regulated-products-current-shortages
U.S. Food & Drug Administration, 2024. CDER Drug Shortages File. [Online] Available at: https://www.accessdata.fda.gov/scripts/drugshortages/Drugshortages.cfm
U.S. Food & Drug Administration, 2024. Currently Approved CBER NDAs/ANDAs By Applicant. [Online] Available at: https://www.fda.gov/media/76386/download
U.S. Food & Drug Administration, 2024. Drug Shortages. [Online] Available at: https://www.fda.gov/drugs/drug-safety-and-availability/drug-shortages [Accessed 2024].
U.S. Food & Drug Administration, 2024. FDA Drug Shortages. [Online] Available at: https://www.accessdata.fda.gov/scripts/drugshortages/default.cfm
U.S. Food & Drug Administration, 2024. FDA Drug Shortages Frequently Asked Questions. [Online] Available at: https://www.accessdata.fda.gov/scripts/drugshortages/dsp_faq.cfm#updates [Accessed 2024].
U.S. Food & Drug Administration, 2024. Purple Book Database of Licensed Biological Products. [Online] Available at: https://purplebooksearch.fda.gov/downloads
U.S. Food and Drug Administration, 2020. Drug Shortages: Root Causes and Potential Solutions, s.l.: s.n.
U.S. Government Accountability Office, 2016. Drug Shortages: Certain Factors Are Strongly Associated with This Persistent Public Health Challenge, s.l.: s.n.
U.S. Securities and Exchange Commission, 2020. Financial Reporting Manual. [Online] Available at: https://www.sec.gov/corpfin/cf-manual/topic-2 [Accessed 2024].
WHO Collaborating Centre for Drug Statistics Methodology, 2024. ATC/DDD Index 2024: J Antiinfectives for Systemic Use. Oslo, Norway: Norwegian Institute of Public Health.
World Health Organization, 2016. Medicines shortages: global approaches to addressing shortages of essential medicines in health systems. WHO Drug Information, 30(2), pp. 180–185.