# GLOSSARY

Acquiring company: In a merger, the company that is subsuming the assets of a target company being merged. In an acquisition, the company buying or otherwise acquiring the assets of the target company.
Acquirer drug: A drug involved in a merger or acquisition and owned by the acquiring company.
Biologic: Also referred to as a biological product. A therapeutic product derived from living human or animal tissue, either through genetic engineering or processing of products such as blood or plasma. Includes both biosimilar biologics approved through the 351(k) pathway (also called “biosimilars”) as well as original biologics approved through the 351(a) pathway.
Brand drug: A drug that is marketed under a brand name or trade name, including both branded small molecule drugs and branded biologic products.
Competitive market (or low-concentration market): A market with an HHI score below 1,000.
Development stages: The major steps in the lifecycle of a new drug, including drug discovery, preclinical testing, phase I clinical trials, phase II clinical trials, phase III clinical trials, and marketing once approved.
Drug technology: The branch of pharmaceutical manufacturing of the primary asset in the M&A deal. We aggregated the drug technology variable in DealForma, and options include small molecules, biologics, dosage form technology, or other (e.g., genomics, microarrays, compound libraries).
Drug quantity sold: Also referred to as volume sales. We measured the quantity of drug sold using total mass in kilograms (kg) or total activity in International Units (IU) of the API in the finished drug product.
Drugs involved in an M&A transaction: In this report, marketed drugs are identified as being “involved” in an M&A if they (a) were owned by the target company and transferred to the acquirer, (b) were brand drugs owned by the acquirer with a shared therapeutic area as one of the target drugs, (c) they were generic drugs owned by the acquirer with a shared dosage form as one of the target drugs.
Essential medicines: Medicines listed on the Advanced Regenerative Manufacturing Institute (ARMI) Essential Medicine List (EML) or the Executive Order Essential Medicines List published by FDA.
Generic drug: A small molecule drug approved through an Abbreviated New Drug Application that is bioequivalent to a reference product, i.e., a brand drug.
HHI: Herfindahl-Hirschman Index, which measures market concentration and is calculated by summing the squared market shares of each company competing in the market.
Highly concentrated market: A market with an HHI score greater than 1,800.
Mergers and acquisitions: Technically, mergers are defined as two companies joining together by mutual agreement to form a new, third company. In practice, mergers often comprise a large company merging with a smaller one to gain one or more desirable assets, obtain new expertise or production capabilities, or facilitate expansion. Acquisitions are usually more direct purchases of another company, either through stock acquisition, bankruptcy auction, partnership buyouts, or other mechanism.
Moderately concentrated market: A market with an HHI score between 1,000 and 1,800.
Target company: The business entity that a (usually larger) pharmaceutical company wants to acquire or merge with in order to obtain the target company’s assets or expand its own capabilities.
Target drug: A drug involved in a merger or acquisition and owned by the target company.
Therapeutic area: For this document, therapeutic area is used as an umbrella term to include some therapeutic classes of drugs—e.g., anti-infectives, immunomodulators—as well as representing specific fields of medicine that focus on particular diseases, body systems, or groups of organs, e.g., cardiology, oncology, pulmonology, genitourinary, etc.
Transaction value: The total value of cash and all other forms of payment made to the target company plus the value of the target’s outstanding net debt if applicable. This typically includes payments of cash and/or stock but can also include notes, convertible debt, preferred stock, etc.