# ACKNOWLEDGEMENTS

We gratefully acknowledge Trinidad Beleche (HHS/OS/ASPE), Oluwarantimi Adetunji (HHS/OS/ASPE), Kathleen Miller (HHS/OS/ASPE), and Andrea Monge (HHS/OS/ASPE) for their leadership, guidance, and input throughout this study. We would like to thank all federal experts for providing guidance and/or review of the study report and findings, including Katherine Bent (HHS/OS/ASPE), Laina Bush (HHS/OS/ASPE), and Rebecca Haffajee (HHS/OS/ASPE). Finally, we are grateful to Ayesha Berlind (ERG) and Andreas Lord (ERG) for their guidance and review of the report.