# EXECUTIVE SUMMARY

In recent decades, the pharmaceutical industry has become increasingly concentrated in the United States, in part due to mergers and acquisitions (M&As) between drug manufacturers. This consolidation from M&As has been cited as a key factor affecting drug prices and drug shortages (U.S. Federal Trade Commission, 2022). In this study, we assessed trends in pharmaceutical M&As during 2010–2023 and evaluated the characteristics of drugs and companies involved in those M&As. We considered the effects of M&As on market concentration, drug prices, drug quantity sold, and drug shortages. We also considered how these associations vary by drug characteristics, including brand drugs versus generics, small molecule (i.e., chemical) drugs versus biological products, and essential medicines versus drugs not on essential medicines lists (EMLs). We used a combination of public and proprietary data sources on M&As, drug sales, drug shortages, and essential medicines. To establish drug ownership at the time of an M&A, we accessed historical archives of various U.S. Food & Drug Administration (FDA) datasets containing drug sponsor and application information, including Approved Drug Products with Therapeutic Equivalence Evaluations (commonly known as the Orange Book), the Purple Book, and the National Drug Code (NDC) Directory, among others. Figure ES-1 presents the main results of our study, which are discussed below.

From 2010–2016, the annual number of M&As in the pharmaceutical sector increased from just under 200 to 267. Thereafter, the numbers began to decline, going from 214 M&As in 2017 to 182 in 2023.^1^ (See Figure ES-1A.) The years 2015 and 2016 were particularly active, with 2015 having the highest total transaction value ($314 billion)^2^ and 2016 having the highest number of M&As (n=267). While there was no change, on average, in the annual number of pharmaceutical M&As across the full study period, the annual number of very high-value M&As of over $1 billion nearly doubled from 2010 to 2023 and accounted for 92.2 percent of the total M&A transaction value in 2023. The growing number of these high-value M&As is notable because drugs involved in transactions valued over $1 billion had higher odds of going into shortage within two years of the M&A date compared to similar drugs not involved in M&As (p = 0.0198).^3^

The therapeutic areas most frequently targeted for M&As were oncology (n=207 M&As or 24.8 percent^4^), followed by central nervous system disorders (n=127 or 15.2 percent) and anti-infectives (n=123 or 14.7 percent). Together, these three therapeutic areas accounted for over half of all M&As from 2010 to 2023 (see Figure ES-1B).^5^ The relative frequency of oncology drug companies among M&A targets grew steadily, from 20.4 percent of M&As in 2010 to a peak of 34.8 percent in 2021. Anti-infective and vaccine-related M&As decreased from 2014 to 2019 but then increased from 2019 to 2023. This increase was driven in part by an increase in vaccine target companies during the same period—possibly a result of the COVID-19 pandemic.^6^ Companies that make approved drugs were the most frequent M&A targets at the beginning of the study period, but their frequency dropped from 46.8 percent of M&As completed in 2010–2015 to only 28.6 percent of M&As in 2016–2021, when the leading asset’s development stage was known. Preclinical drugs were the primary targets in just 8.7 percent of M&As occurring in 2010–2021, but rose to 16.2 percent in 2022–2023.

In the 12 months following an M&A, the market concentration increased by 5.9 percent, on average, when defining markets by therapeutic area. We divided the pharmaceutical sector into 14 markets based on therapeutic areas and evaluated each market’s concentration using the Herfindahl-Hirschman Index (HHI). For each market, we calculated the average HHI over the study period and classified the market as highly concentrated, moderately concentrated, or competitive, according to U.S. Department of Justice guidelines (U.S. Department of Justice, 2024). Genitourinary drugs experienced the largest average increase in HHI of 27.6 percent in the year following an M&A, followed by gastrointestinal drugs (15.9 percent increase per M&A) and hematology drugs (13.5 percent increase per M&A). M&As in markets with high average concentration tended to produce larger increases in HHI (average increase of 171 points) than markets with moderate average concentration (average increase of 101 points) or markets that were competitive on average (average increase of only 9 points). Interestingly, M&As were associated with lower odds of drug shortage in highly concentrated markets (p = 0.0465) but were associated with elevated odds of drug shortage in competitive markets with low concentration (p = 0.0055).

Following an M&A, there was a decrease in the drug quantity sold, which we measured by the amount of active pharmaceutical ingredient (API) in the finished drug product that was sold, both for drugs involved in M&As and comparable drugs not involved in M&As. Generic drugs involved in M&As, however, experienced a more rapid decline in quantity sold than comparable non-M&A generics (see Figure ES-1C). Decreasing supply is a precursor to many (though not all) drug shortages. The accelerated declines that we observed in quantity sold are consistent with our finding that generic drugs involved in M&As have increased odds of going into shortage compared to similar non-M&A generics (p = 0.0202). Within the sample, M&As were associated with a more gradual decline in brand drugs’ quantity sold, but the association was weak.

Price trends following an M&A differed between generic and brand drugs, based on our analysis of the IQVIA National Sales Perspective (NSP) invoice price and the wholesale acquisition cost (WAC). For generics, the NSP invoice price and the WAC decreased both for M&A drugs and for comparable non-M&A drugs, but the average NSP invoice price declined more slowly for generics involved in M&As. This was a relatively small and short-term effect that lasted for one year after the transaction but had dissipated by the end of the second year after the M&A. In contrast, brand drugs experienced increasing NSP prices and WACs after an M&A. Brands involved in M&As had higher WAC growth in the six months immediately after the transaction, rising by 3.7 percent on average, compared to only 2.1 percent for similar non-M&A brand drugs (p = 0.0032).

Drugs involved in an M&A had 24.3 percent higher odds of going into shortage within two years of the transaction date compared to similar drugs not involved in M&As during the same time (p = 0.0249). Among generic drugs specifically, there was a 26.4 percent increase in the odds of a drug going into shortage if the company was involved in an M&A, compared to similar drugs not involved in M&As (p = 0.0202) (see Figure ES-1D). This finding is particularly salient as generic drugs already have the highest baseline risk of going into shortage (Schweitzer, 2013; U.S. Food and Drug Administration, 2020; The White House, 2021; Gagnon & Volesky, 2017). Our study did not find evidence that brand drugs involved in M&As go into shortage at higher rates than brands not involved in M&As (odds ratio = 1.02, p = 0.9453).

When analyzing generic and brand drugs collectively, M&As were associated with significantly higher shortage risk for the target company’s drugs, but not for the acquiring company’s drugs. We also found that essential medicines had 13.6 percent higher odds of going into shortage within two years if they had been involved in an M&A, though this association was weak (p = 0.5528). Essential medicines listed on the Advanced Regenerative Manufacturing Institute (ARMI) EML had 11.6 percent higher odds of being involved in an M&A than drugs not included on the ARMI EML (p = 0.0307).^7^ Many of these essential drugs already have high baseline shortage risks and histories of drug shortage, and the possibility that this risk may increase further when involved in an M&A is notable.

This study has several limitations. First, we did not account for parent companies, subsidiaries, or other corporate structures when assessing drug ownership. In our drug-level analysis, we only included M&As in which the target company or acquiring company was a sponsor of a U.S. drug application at the time of the transaction. Second, we relied on the North American Industry Classification System (NAICS) to identify pharmaceutical companies, which relies on self-reporting and may contain errors. The intended focus of the study was on U.S. markets, but the pharmaceutical industry is global by nature, and our analysis of M&As from 2010–2023 was not limited to transactions between companies headquartered in the United States. This may have led to the inclusion of some M&As focused on non-U.S. markets. Any such M&As, however, were excluded from the drug analysis, which only covered prescription drugs marketed in the United States.

While our drug analysis was intended to include all prescription drugs marketed in the United States from 2018 to 2023, some drugs were likely omitted due to incomplete coverage in the underlying data and records failing to match across datasets, which could have affected our HHI calculations. Additionally, we used FDA’s drug shortage list, which includes national shortages only. Our analysis does not capture the extent to which M&As affect availability of drugs at local or regional levels. It should also be noted that our drug-level analysis was performed for the period 2018–2023, which included the COVID-19 pandemic and two years of relatively high inflation. Temporary effects of the pandemic on drug prices, drug quantity sold, supply, and shortages may affect our findings. Finally, while our drug-level analysis aimed to reduce imbalances between a cohort of M&A drugs and a cohort of non-M&A drugs, additional evidence and analysis may be needed before the associations presented in this report can be interpreted as causal relationships. M&As are one of a variety of factors that can influence drug prices, drug quantities sold, shortages, or market concentration, and our study accounts for some but not all possible confounders.

Future research should investigate how M&As affect the number of manufacturers in pharmaceutical markets and the geographical dispersion of manufacturers. These changes could contribute to a less diversified pharmaceutical supply chain and negatively affect manufacturers’ ability to respond to sudden changes in supply or demand. Additionally, the pharmaceutical supply chains are typically complex, and M&As involving supply chain intermediaries also likely impact drug shortage risks. Our study was focused on drug manufacturers, but medical device companies, wholesalers, pharmacies, pharmacy benefit managers (PBMs), and insurance companies can often affect the resiliency of the pharmaceutical supply chain. PBMs often negotiate exclusive contracts with a single drug manufacturer in exchange for lower prices of a drug, which could tend to reduce the number of suppliers for that drug—particularly given that the PBM sector is highly concentrated in the United States. Evaluating changes in formularies and in the number of suppliers may provide additional insights into drug shortage risk. Wholesalers, which are also highly concentrated in the U.S. pharmaceutical supply chains, often act as price setters in generic drug markets and can negotiate lower prices when there are multiple generic suppliers of a drug. Evaluating the impact of M&As with or between other supply chain intermediaries is a useful area for further study.

Figure ES-1 Overview of Results

Figure ES-1 has four panels entitled “A. M&A Counts and Deal Values, 2010 through 2023,” “B. Characteristics of Target Companies, 2010 through 2023,” “C. Impact of M&As on Quantity Sold and Price,” and “D. Association between M&As and New Shortage.” Panel A shows a fluctuating number of M&As per year and median deal value, with both spiking around 2015. Panel B shows an increase in M&As that target companies focused on early-stage drug development and an increase in target companies focused on oncology drugs. Panel C shows that M&As are associated with an upward effect on brand drugs’ quantity sold and a downward effect on generic drugs’ quantity sold. M&As are associated with an upward effect on generic drugs’ IQVIA NSP invoice price but no effect on brand drugs’ IQVIA NSP invoice price. M&As are associated with an upward effect on generic drugs’ WAC prices which grows over time and an upward effect on brand drugs’ WAC prices which decreases in strength over time. Panel D shows that M&As are associated with elevated odds of a drug going into shortage within two years of the transaction date, particularly for all drugs, generic drugs, the target company’s drugs, drugs valued over 1 billion dollars, and drugs in competitive markets with low concentration. Drugs in noncompetitive markets with high concentration were associated with lower odds of going into shortage within two years of the M&A date.

1 It should be noted that we excluded M&As involving cell and gene therapies, diagnostics, and medical devices.

2 All monetary values are expressed in 2023 U.S. dollars. The sample estimate of $314 billion was calculated from M&As with known transaction values, which made up 60.8 percent of all M&As in 2015. Across all study years, 59.7 percent of M&As had known transaction values, and the annual rates of missing transaction values varied little.

3 We define drugs “involved” in a transaction to include drugs owned by the target company and transferred to the acquirer, brand drugs owned by the acquirer with a shared therapeutic area as one of the target drugs, and generic drugs owned by the acquirer with a shared dosage form as one of the target drugs.

4 In total, 835 M&As in our sample had a known and applicable therapeutic area, as reported in DealForma.

5 Statistics are based on M&As for which there is an applicable and known therapeutic area. Therapeutic area was identified using DealForma data and is assigned to companies based on the therapeutic area of their leading asset.

6 We included vaccines in the anti-infective therapeutic area, consistent with the Anatomical Therapeutic Chemical (ATC) classification system (WHO Collaborating Centre for Drug Statistics Methodology, 2024).

7 The ARMI EML was funded by the Department of Health & Human Services’ (HHS) Office of the Assistant Secretary for Preparedness and Response (ASPR).