# 7 CONCLUSION

We evaluated the characteristics of 3,006 M&As between pharmaceutical manufacturers from January 2010 through December 2023. In our sample, transaction values increased over time, in part due to a growing number of high-value pharmaceutical M&As. M&A activity and annual transaction value peaked in 2015–2016. There were some more recent indications of increasing consolidation between companies working in different pharmaceutical industries. Moreover, mergers and acquisitions (rather than asset transfers or divestitures) have made up a growing share of pharmaceutical M&As in recent years. There has been a shift away from acquiring private companies, with more targets being publicly traded pharmaceutical companies that are smaller than the acquirer. Approved drugs have declined as the focus of pharmaceutical M&As and have been replaced by companies working in early-stage drug development. Companies with oncology drugs made up the biggest therapeutic category among M&A target companies, mainly in the final years of the study period. After an M&A, both generic and brand drugs experienced decreases in quantity sold, and the decline was faster for generics involved in M&As compared to similar generics not involved in M&As. Overall, we found that M&As are associated with an increase in the risk of drug shortages. Generic drugs in particular were significantly more likely to go into shortage within the two years after an M&A than were similar non-M&A drugs. Elevations in the risks of generic drug shortages and, possibly, essential medicines could have large impacts on the U.S. drug market because generics and essential medicines already have high baseline levels of drug shortage risk.