# 6 DISCUSSION

## 6.1 Overall Findings

M&A activity in the pharmaceutical industry is common, and literature suggests M&As may affect prices, supply, and market competition. In our sample, 11.3 percent of drugs were involved in M&As, and the public health impact of even a single shortage after an M&A can be substantial. M&As occur for many reasons, e.g., to increase market power; to reduce risk through diversification; to take advantage of economies of scale and scope; and to reap tax advantages. In the pharmaceutical industry, consolidating the operations of two companies can yield gains in manufacturing and marketing efficiency, higher returns, and/or more effective bundling of therapeutic area portfolios, thereby improving a company’s bargaining power with supply chain intermediaries, including prescribers. M&As can also represent a shift in strategic focus or a response to market competition. For example, acquisitions may prevent a competitor from buying key assets. Additionally, acquisition of companies with products in early-stage development can also allow companies to maintain their drug pipelines in the face of patent expirations, unanticipated failures in clinical trials, or increased competition.

During our study period, 2010–2023, we observe two trends for M&As in the pharmaceutical industry—a shift toward higher-value deals and an increase in early-stage product acquisitions. While median deal value increased slightly from 2010 through 2023, much of the growth in deal values was attributable to an increasing frequency of M&As valued over $1 billion. These high-value deals tend to be conducted by large pharmaceutical companies and may increase their market share—particularly because a high valuation also generally involves a large target company and thus represents a substantial consolidation of the market. The market share held by the four, eight, or 20 largest firms is an important metric of market concentration (Feldman, et al., 2022), and the rise in the frequency of high-value M&As could signal an overall reduction in market competition in the pharmaceutical sector over this period. Even though our study did not account for confounding factors, such as new product launches, changes in patient population, and demand, we did observe an increase in HHI from 2018–2023, on average, and this increase coincided with a rise in high-value M&As. In 2010, there were only 11 pharmaceutical deals valued over $1 billion, but in 2023, there were 21. Deals over $1 billion made up a disproportionate share of total deal value (in dollars) during 2010–2023, even though they were far less common than those under $1 billion.^30^

Several of the largest pharmaceutical companies completed as many M&As valued over $1 billion in 2021–2023 as they did in the preceding 11 years from 2010–2020. For example, Pfizer—which became the first drug company to exceed $100 billion in annual sales partly due to the success of its COVID-19 vaccine (Carey, 2023)—completed 10 M&As exceeding $1 billion in 2010–2023. Half of these M&As occurred in 2021-2023. Sanofi completed 11 M&As each valued over $1 billion from 2010–2023, with five of them occurring in the last three years (2021–2023). Amgen and Eli Lilly both completed nine such M&As, and four were completed in 2021–2023.

The growing focus on acquiring companies with early-stage products was visible from 2010–2023 and was particularly pronounced in 2021–2023, when preclinical drug companies made up the largest share of M&A targets (13.8 to 19.6 percent depending on the year). This likely represents an effort by pharmaceutical companies to invest in innovator drugs to maintain a strong development pipeline. In fact, 2021 and 2022 were the first years in the study period when the proportion of M&As involving early-stage development companies was greater than that involving late-stage development or approved drug companies. Interest rates began rising in 2022, which likely created challenges with debt financing, and there may have been an uptick in early-stage companies seeking to be acquired (Bernauer, et al., 2024). This interest was apparently reciprocated by acquirers, which were willing to dedicate a larger proportion of their M&A investments to acquiring early-stage companies and products compared to previous years. The level of investment in acquiring early-stage products implies that R&D activity in the pharmaceutical market remains robust. M&As targeting companies with approved products were relatively constant during 2016–2020 but experienced a significant decrease during 2020–2021. M&As involving approved products returned to their pre-COVID levels from 2022 onward.

In addition to using M&As to maintain robust pipelines of innovator drugs, companies also frequently used M&As to acquire approved products, many of which are generics. Generic drugs have some of the highest baseline risks of going into shortage (Schweitzer, 2013; U.S. Food and Drug Administration, 2020; The White House, 2021; Gagnon & Volesky, 2017). We found that these risks were even higher for generic drugs involved in M&As. During 2018–2023, generic drugs involved in an M&A had 26.4 percent higher odds of going into shortage within two years of the M&A date compared to similar generics not involved in an M&A (p = 0.0202). The shortage risk was even more elevated for generic drugs owned by the target company (odds ratio = 2.58, p < 0.0001). This elevation in shortage risk may be indicative of post-M&A strategies intended to extract value from the deal. Following an acquisition, companies may take advantage of economies of scale and/or scope (Hammoudeh & Nain, 2024), for example by consolidating manufacturing lines, combining duplicate divisions (R&D, corporate, purchasing, etc.), using higher purchasing power to negotiate lower raw material costs, reducing excess inventory/carrying costs, or relocating manufacturing plants abroad. These measures often increase shortage risk by reducing manufacturers’ supply resiliency. Unexpected production disruptions due to manufacturing quality issues, natural disasters, or other factors affecting a single company can have significant ramifications for patients when that company’s product comprises a large portion of the market supply for that drug. The impact of M&As may be substantial; 11.3 percent of drugs in our overall drug dataset were involved in M&As at some point during the six-year period, when counting both the target’s drugs and the acquirer’s relevant drugs.

For generic drugs, M&As were associated with a large downward effect on quantity sold and a modest upward effect on prices. The downward effect on quantity sold grew in magnitude during the two years after an M&A. We find that quantity sold decreased by an average of 41.2 percent for generic drugs involved in M&As, compared to a 32.9 percent decrease for comparable non-M&A generics (p = 0.0562) by the end of the second year. A reduction in quantity sold is a common precursor to some (but not all) drug shortages (U.S. Food and Drug Administration, 2020), and the accelerated decline is consistent with our finding that generic drugs involved in M&As have a higher odds of going into shortage. The impact on prices was much smaller and more difficult to discern due to greater uncertainty and wide variation in price growth among the drugs in our sample. Two years after an M&A, we find that generic WACs declined by 11.9 percent, compared to 10.0 percent for similar drugs that were not involved in M&As (p = 0.1139). M&As were also associated with a slight upward effect on the NSP invoice price, but this effect was less than 3 percent and disappeared during the second year after an M&A. Differences in price of a few percentage points are very small in dollar terms given how inexpensive generic drugs are.

For brand drugs, M&As were associated with an upward effect on WACs or list prices but virtually no effect on NSP invoice prices. This discrepancy may provide insight into how brand manufacturers extract value after an M&A. Larger increases in the WAC likely indicate more cost to the payer and healthcare plan, as WACs are often used as benchmarks for negotiating reimbursement rates. Yet, while manufacturers control the WAC and decide whether to increase the drug’s list price, these higher payments may not be reaching the manufacturer. There are many intermediaries in the pharmaceutical supply chain that handle the drug or process the claim, including the healthcare provider (e.g., hospitals, clinics, pharmacies), the insurance company and/or pharmacy benefit manager (PBM), and the wholesaler. All of these entities have the potential to capture the increase in payments when the manufacturer raises their list price. This may, in fact, be what happens following an M&A. Compared to the WAC, the NSP invoice price is a better (but still limited) representation of what manufacturers actually earn from the sale of their drugs. Our finding that WACs rise more rapidly after an M&A, but NSP invoice prices do not, suggests that manufacturers may be raising brand drug list prices without invoicing providers at higher rates. In effect, manufacturers may be allowing supply chain intermediaries to keep the increases in payment from the beneficiary and payer/healthcare plan.

While the manufacturer may not be receiving higher net payments for the brand drug, these pricing dynamics would make the manufacturer’s product more profitable to the supply chain intermediaries, which could increase the drug’s volume sales. The differential trends in the WAC and NSP invoice prices therefore could generate higher volume sales and more total revenue for the manufacturer. This dynamic is consistent with our finding that M&As were associated with an upward effect on quantity sold, which appeared to grow over time. Because of larger uncertainty, this effect was most discernible in the second year after an M&A, at which time brand drug quantity sold had dropped by 24.4 percent compared to 31.9 percent for their non-M&A counterparts (p = 0.0822). While this upward effect on quantity sold was most visible two years after the M&A, WACs only grew noticeably faster in the first six months (p = 0.0032). By the end of the second year after the M&A, brand drug WACs had increased as much as non-M&A brand drugs, on average.

This finding of a short-term upward effect on brand drug prices is consistent with the literature. For example, Feng et al. (2023) found that WAC prices increased for branded on-patent drugs involved in horizontal M&As with low transaction values (defined as having a transaction value below $200 million). Bonaime and Wang (2024) found that, when acquirers and targets had similar product offerings, average prices of the acquirer’s drugs increased by 2.2 percent, but the effect only lasted for about one year after the M&A.

## 6.2 Strengths and Limitations

This study has several strengths. Assessing a 14-year study period from 2010–2023 provides insight into year-to-year variation and facilitates the identification of broader longitudinal trends. Additionally, we used historical data from the Orange Book, Purple Book, and CBER NDA/ANDA to reconstruct drug ownership at the time of the M&A, which allowed linkage with drug-level sales data using historical archives of the NDC Directory. We also assembled historical archives of the FDA drug shortage lists, which expanded the analysis beyond ongoing or recently resolved shortages. The cohort analysis of drug shortages provides greater evidence of a link to M&As because we removed imbalance in confounders and compared M&A drugs to non-M&A drugs over the same time period.

The study also has limitations. Our analysis of M&As was limited in its ability to assess the prevalence of vertical versus horizontal integrations, since most forms of vertical integration were excluded by our inclusion criteria and by our study’s focus on pharmaceutical manufacturers specifically. The intended focus of the study was on U.S. markets, but the pharmaceutical industry is highly global, and we did not exclude M&As based on the companies’ geographic locations. This may have led to some M&As being included in our study that were focused on non-U.S. markets.

In the drug-level analysis, we used the period from 2018 through 2023 to assess shortages, pricing changes, and drug quantity sold after an M&A. This period included the COVID-19 pandemic as well as two years of high inflation. Transitory effects of the pandemic may have affected our findings. Additionally, not all drug data could be used in the cohort analysis because some M&A drugs do not have any matching non-M&A drugs. This reduced the statistical power, particularly for subgroup analyses. In our drug analysis, we attempted to include all prescription drugs marketed in the United States from 2018–2023, but omissions occurred due to incomplete coverage in the underlying data sources.^31^ These omissions may have upwardly biased the HHI calculations, since the omitted companies make their markets more competitive than we estimated using the available data. In addition, calculations of HHI are based on defining a market by the aggregate therapeutic class, a procedure that can be too broad in some circumstances and too narrow in others (Feldman, et al., 2022). When assessing mergers, DOJ and FTC use product substitutability to define markets of products that compete with each other (U.S. Department of Justice and the Federal Trade Commission, 2023). While we used therapeutic area as an approximate definition of a pharmaceutical market, many products sold in the same aggregate therapeutic area are not substitutable or in direct competition. Using smaller markets would likely lead to higher estimates of HHI than we present in our study.

Our analysis focused on the company most directly involved in the manufacture of a given drug, as indicated by the ownership of the drug application according to FDA sources. In some cases, after an M&A, the target company continued to exist as a subsidiary of the acquirer. Subsidiaries or inactive companies that may have continued to be listed as the drug sponsor in FDA data sources (e.g., the Orange and Purple Books) were not collapsed into their parent companies. Not accounting for parent companies and corporate structures could negatively bias our HHI calculations and cause underestimates of the true concentration of pharmaceutical markets. Additionally, the selection of FDA’s drug shortage list allowed us to study drug shortages that had the most impact. However, FDA’s drug shortage list only includes national shortages, and our analysis does not capture the extent to which M&As affect availability of drugs at a sub-national level. There are likely some supply shortfalls that occurred during the study period that were attributable to an M&A but were excluded from the FDA shortage list because other market participants were able to meet the demand. Finally, while our drug-level analysis aimed to reduce imbalances between the M&A cohort of drugs and the non-M&A cohort of drugs, additional evidence and analyses are needed before the associations we present can be interpreted as causal. M&As are one of a variety of factors that can influence drug prices, the quantity of drug sold, shortages, or market concentration, and our study accounts for some but not all possible confounders.

## 6.3 Future Directions

One promising area of further research is a broader analysis of vertical integrations beyond pharmaceutical manufacturers. Drug prices, quantities sold, and shortages may be affected by M&As involving intermediaries of the pharmaceutical supply chain that do not conventionally manufacture drugs. Nevertheless, we excluded medical device companies, wholesalers, distributors, pharmacies, PBMs, and insurance companies from the study unless they had been classified in one of the pharmaceutical manufacturing NAICS. Increasingly, however, these other intermediaries are merging with or acquiring manufacturing companies, or they are engaging in M&As that may affect the number of drug suppliers in the market. In 2020, Blue Cross Blue Shield, one of the largest insurance companies, partnered with Civica Rx, a non-profit drug company, as part of an attempt to manufacture lower-priced generic drugs (Jaspen, 2020). In 2023, CVS Health Corp launched Cordavis, “a wholly owned subsidiary that will work directly with manufacturers to commercialize and/or co-produce biosimilar products” (CVS Health, 2023).

A similar company called NUVAILA was launched in 2024 by Optum Health Solutions, a subsidiary of OptumRx (Fein, 2024), the second largest PBM in the United States based on market share (Guardado, 2024). PBMs create formularies that influence drug use in the pharmaceutical market, particularly of retail drugs. Negotiations conducted by PBMs can lead to exclusive contracts with a single drug manufacturer in exchange for lower prices (U.S. Federal Trade Commission, 2024), which could reduce the number of drug suppliers, thereby increasing the risk of drug shortages. This is particularly relevant given the consolidation of PBMs and health insurers in the United States. Similar dynamics can exist with wholesalers, which are also highly concentrated in the United States and often act as price setters in generic drug markets. Evaluating the effects of M&As involving other supply chain intermediaries would be a useful area of further study.

Future research into how M&As affect the number of manufacturers in pharmaceutical markets and the geographical dispersion of manufacturers would also be useful. These changes could contribute to a less diversified pharmaceutical supply chain and could impact manufacturers’ ability to respond nimbly to sudden changes in supply or demand. As generics are historically the most prone to shortage, further research related to the impact of M&As on geographical dispersion of the supply chain for generics would also be useful (The White House, 2021).

30 Over the full 14-year study period, only 14.0 percent of all deals with known transaction value exceeded $1 billion.

31 Some 9-digit NDCs listed in IQVIA NSP were not retained in our final drug dataset because they did not have matching records in the drug ownership datasets, the NDC Directory, or both. This led to a 2.1 percent reduction in total sales due to exclusions of non-matching NDCs, but some of the non-matching drugs may have been appropriately excluded because they were out of scope (e.g., including OTCs).