# 5 RESULTS

## 5.1 Frequency and Type of Pharmaceutical M&As

### 5.1.1 Overall Trends

The number of pharmaceutical M&As per year ranged from a minimum of 174 in 2012 to a maximum of 267 in 2016 (see Figure 2). The annual M&A frequency varied widely and did not show a clear trend over the study period, though there was a decline in the number of M&As over the last three years analyzed, 2021–2023. The median and average transaction values both contained high variation but had a peak in 2015, which coincided with high M&A activity. In 2015, total M&A transaction value was $314 billion (not shown). In comparison, total transaction value was $74.9 billion in 2010, the first year of the study, and $143 billion at the end of the study time period (in 2023). Over the study period, the median value per M&A grew by 2.4 percent annually, and the mean M&A deal value grew by 5.8 percent annually, but these trends were not strongly distinguishable from year-to-year variation (p = 0.3387 and p = 0.1189, respectively).

Figure 2 M&A Counts and Median M&A Deal Values, 2010–2023

This graph shows the number of M&A deals each year from 2010 to 2023 and the median transaction value of those M&A deals, when known. A two-piece model shows increasing number of deals from 2010 to 2015 followed by a decrease from 2016 to 2023, but year-to-year variation is high. The median deal value also fluctuates heavily, with a large spike in 2015.

Data Source: 3,006 in-scope M&As identified in FactSet, of which 1,794 (59.7%) had a known transaction value. Transaction values were inflated to 2023 dollars using the consumer price index for medical care, seasonally adjusted (U.S. Bureau of Labor Statistics, 2024). The piecewise linear model identified the year 2015 as a break point when the trend in annual number of M&As changed (p = 0.0716 using Davies’ test). These counts represent the universe of M&As for 2010–2023 that met our inclusion criteria.

Transaction values were heavily right-skewed, with some M&As having significantly higher transaction values. In the sample, these highest-value M&A deals exhibited some distinct trends (see Figure 3). Among M&As with a known transaction value,^15^ there was a slight decline in M&As valued below $1 billion, and a slight rise in M&As valued over $1 billion, though these trends were not easy to distinguish from year-to-year variation (p = 0.1200 and p = 0.2450, respectively). M&As valued at over $1 billion, however, made up a growing share of total annual transaction dollars, and this trend was statistically significant (p = 0.0320). In 2023, M&As valued over $1 billion made up 92.2 percent of the total M&A transaction value. While the number of M&As valued below $1 billion may be decreasing, the observed growth in median transaction values in our sample suggests mid-value M&As may also be rising in value. Within the lower-valued M&As, trends were highly similar between M&As valued at <$500 million and M&As valued at $500 million to $1 billion.

Figure 3 Trends in High-Value M&A Deals, 2010–2023

Note: Black line shows fitted linear trend. Gray area shows standard error in fitted trend. Prior to fitting linear trends, we checked for homoscedasticity,^16^ normality, and independence. The slope of the left graph is the average change in number of M&A deals per year. The slope of the right graph is the average change in percentage of total deal value per year (e.g., an increase of 1.2 percentage points per year for M&As over $1 billion).

This graph has two panels: number of deals from 2010 to 2023 and percent of total deal value during the same time. These graphs show that deals valued under 1 billion dollars made up a majority of total M&A deals but decreased in frequency from 2010 to 2023. Despite making up the majority of transactions, these M&As valued under 1 billion dollars accounted for a minority of total transaction value in any given year. M&As valued over 1 billion dollars became more frequent and comprised a growing share of total M&A transaction value.

Data Source: FactSet (2010–2023).

Transactions valued at over $500 million or from $100–$500 million accounted for the largest shares of M&As, with each comprising 23.6 percent of M&As from 2010–2023 (see Figure 4A, below). Mid-sized M&As of $25–$100 million made up 20.7 percent of M&As. Small M&As of $5–$25 million and less than $5 million accounted for 18.7 percent and 13.4 percent of all M&As, respectively. The two lowest-value M&A groups (<$5 million and $5–$25 million) are the most likely to include failed ventures in which the company’s assets were acquired during liquidation.

Figure 4 Characteristics of M&As and Target Companies, 2010–2023

N/A = not applicable. For additional numerical tabulations, see Table B - 3.

[a] Target companies that make both brand drugs and generic drugs are classified by DealForma according to the highest-selling product, which would typically be a brand drug and not a generic drug.

Figure 4 has six panels labeled “A. Transaction Value (sample size of 1,794 M&As),” “B. Therapeutic Area (sample size of 835 M&As)”, “C. Primary Technology (sample size equals 861 M&As),” “D. Type of Deal (sample size equals 2,179),” “E. Phase of Development (sample size equals 987),” and “F. Highest-Value Asset (sample size equals 469).” Panel A shows that deals valued over 500 million dollars made up a growing share of all pharmaceutical M&As. Panel B shows that companies focused on oncology drugs have also become more frequent targets. Panel C shows that the majority of M&As involve small molecule technology, though biologics have grown in relative frequency. Panel D shows that acquisitions are most common, followed by asset transfers or divestitures, with only a very small number of mergers. Panel E shows that M&As targeting approved drugs have become less frequent since 2010, and there has been growth in M&As targeting companies focused on preclinical drugs. Panel F shows that almost all target companies are classified as brand drug companies, but this may underrepresent companies making generic drugs, since this classification is based on the company’s leading asset, and brand drugs typically earn higher sales than generic drugs.

Data Sources: FactSet (2010–2023) and DealForma (2010–2023).

For most therapeutic areas, the acquisition rate did not show major trends (see Figure 4B). In our sample, target companies that focused on oncology drugs, however, saw a substantial increase in relative M&A activity, rising from 20.4 percent of M&As in 2010 to a peak of 34.8 percent in 2021. M&As targeting companies with infectious disease drugs were decreasing from 2014–2019, but then began increasing after 2019—possibly a result of the COVID-19 pandemic. In our sample, 835 M&As had a known and applicable therapeutic area, and the most common M&A targets were oncology (n=207 M&As or 24.8 percent), followed by central nervous system (n=127 or 15.2 percent) and anti-infective (n=123 or 14.7 percent).

The leading technology of the target company in M&A was dominated by small molecule drugs, which made up roughly half of all M&As from 2018–2023 with known technology (see Figure 4C). Biological products grew as a target from 2010–2023, partly fueled by an increase in acquisitions involving antibody technology, which tripled from 7.3 percent of M&As in 2010 to 21.7 percent of M&As in 2023. M&As with vaccine technologies made up a relatively small share and were decreasing before 2019, but have been increasing since then, which may partly explain the similar trend seen in infectious disease targets.

Only 2.9 percent of M&As qualified as mergers (see Figure 4D). The other 97.1 percent of M&As were divided roughly equally between acquisitions (52.1 percent) and asset transfers/divestitures (45.0 percent). Acquisitions, however, have become more frequent since 2019. From 2010–2019, acquisitions showed little trend and composed 49.7 percent of all M&As. From 2020–2023, they rose to 58.4 percent of all M&As. In 2021, the relative frequency of acquisitions reached a peak, when they made up 64.3 percent of M&As.

As Figure 4F shows, the target company’s leading asset was a brand drug in 85.3 percent of the M&As from 2018 to 2023 (when known). However, this may create a false impression that most M&As are focused on brand drugs. Many of these “brand drug companies” likely also marketed generics.^17^ In fact, generic drugs are far more common in the 2018–2023 drug sample (discussed below) than Figure 4F might suggest. In our drug sample, the number of generic drugs that we identified as being involved in an M&A was more than twice the number of brand drugs (see Table 2). While Figure 4F shows that the majority of companies are classified as brand drug manufacturers, many of these likely also make generic drugs.

Figure 4E and Figure 5 (below) display a steady decrease in M&As targeting companies with approved drugs, which historically were the most frequent targets. From 2010–2015, approved drug companies were involved in 46.8 percent of M&As in which the leading asset’s development stage was known and applicable. This dropped to only 28.6 percent in the period from 2016–2021. Companies with leading assets in late-stage clinical development (phases II and III) and companies with leading assets in early-stage development saw the reverse trend. M&As involving preclinical drugs, in particular, increased substantially, from 10.5 percent of all M&As in the period 2010–2021 to 18.2 percent in 2022–2023.

Figure 5 Trends in Development Stage of Target Company, 2010–2023

Note: Black line shows fitted linear trend. Gray area shows standard error in fitted trend. Prior to fitting linear trends, we checked for sufficient homoscedasticity, normality, and independence. Graphs exclude M&As for which the stage of development is not relevant or unknown.

This graph shows the percent of M&A deals focused on early-stage development (sample size equals 247), late-stage development (sample size equals 282), and approved drugs (sample size equals 309). Early-stage development which includes drug platforms, drug discovery, preclinical testing, and phase I testing. M&As targeting companies working in these areas have growth steadily from 2010 to 2023. Late-stage development includes phase II and phase III clinical testing and has been roughly constant over the study period. M&As targeting approved drugs have declined rapidly since 2015.

Data Source: FactSet (2010–2023) and DealForma (2010–2023).

### 5.1.2 Industry, Ownership, and Size of Acquirer and Target Companies

A large majority of M&As—77.6 percent—between 2010–2023 involved companies that shared at least one of the four relevant pharmaceutical NAICS codes (see Figure 6).^18^ However, there was also an increase in M&As between pharmaceutical companies that have no overlapping pharmaceutical NAICS codes, as shown in Figure 6.

Most M&As were between two companies that both held the 325412 NAICS designation, i.e., Pharmaceutical Manufacturing, though this percentage has declined from 83.2 percent in 2010 to 61.0 percent in 2023. In contrast, M&As between companies that did not have a mutual NAICS code increased from 7.7 percent in 2010 to 29.1 percent in 2023—almost a 300 percent increase.

This increase in expanding in-house capabilities was focused on acquiring companies in NAICS 541714, Research and Development in Biotechnology (except Nanobiotechnology). In 2010, companies with this biotech R&D NAICS (541714) were involved in less than 1 percent of M&As between companies with nonoverlapping pharmaceutical NAICS codes. By 2023, this had risen to 67.9 percent. This dramatic increase reflects potential consolidation of pharmaceutical manufacturers with pharmaceutical R&D companies.

Figure 6 Company Types and Industries Involved in Pharmaceutical M&As ^[a]^

Note: mfg. serv. = manufacturing services.

[a] Additional information on industry inclusion criteria can be found in Section 4.2. Categorizations account for companies with relevant primary or secondary NAICS.

[b] NAICS 325411 is Medicinal and Botanical Manufacturing; NAICS 325412 is Pharmaceutical Manufacturing; NAICS 325414 is Biological Product (except Diagnostic) Manufacturing; NAICS 541714 is Research and Development in Biotechnology (except Nanobiotechnology).

This graph has two panels: company type (with sample size of 954) and NAICS (with sample size of 3,006). The first panel shows that almost all M&As in the sample can be classified as pharmaceutical companies buying pharmaceutical companies. The second panel shows that most M&As involve companies that are both in NAICS code 325412, pharmaceutical manufacturing. However, there has been large growth in the percent of M&A deals in which the two companies do not share any pharmaceutical NAICS codes.

Data Source: FactSet and DealForma data on M&As from 2010–2023. Using DealForma, company type could be determined for 954 of the M&As that matched to FactSet.

Figure 7 shows select trends among the “pharma buys pharma” group. In our sample, large, medium, and small publicly traded companies all shifted away from buying private companies, as indicated by the downward trend in the top three panels of Figure 7. Instead, publicly traded acquirers focused more on buying smaller public companies, as the bottom three panels show.

Figure 7 Select Trends in Publicly Traded Pharmaceutical Companies Buying Other Pharmaceutical Companies

Note: Blue line shows fitted linear trend. Gray area shows standard error in fitted trend. Before fitting linear trends, we checked for homoscedasticity, normality, and independence. Company size is based on market capitalization; small publicly traded companies have less than $1 billion, medium publicly traded companies have $1 billion to $50 billion, and large publicly traded companies have more than $50 billion. Graphs are only shown for groups with evidence of a trend. For other types of acquisitions (e.g., large public pharma buying small public pharma), there were no substantial trends over the study period.

This graph has six panels showing trends in M&As by the acquirer and target companies’ business structures. From 2010 to 2023, there was a decrease in the relative frequency of large public pharma buying private pharma, medium public pharma buying private pharma, and small public pharma buying private pharma. There was an increase in the relative frequency of large public pharma buying medium public pharma, medium public pharma buying small public pharma, and small public pharma buying small public pharma.

Data Source: FactSet and DealForma data on M&As from 2010–2023.

### 5.1.3 Types of Drugs Involved in M&As

For the subset of M&As from 2018–2023, we matched the acquiring and target companies to the sponsor names in the drug-level data. We then analyzed the characteristics of individual marketed prescription drugs involved in M&As.^19^ Table 2 presents the characteristics of the drugs in the sample that were involved in M&As, using IQVIA data. Most of the target drugs (i.e., those owned by the target company in the M&A) in the sample were generic small molecules (65.0 percent), followed by brand small molecules (30.0 percent) and original biologics (5.0 percent).^20,21^ Among target drugs involved in M&As, most (29.0 percent) had annual IQVIA NSP invoice sales of under $0.5 million, followed by drugs with annual sales between $1 million–$5 million (20.1 percent). Drugs involving the central nervous system were most common in the sample (22.5 percent), followed by dermatology medication (12.1 percent) and pain medication (11.1 percent). Among acquirer drugs involved in M&As, 90.8 percent (n=2,407) were small molecule generics, and 42.5 percent of these had annual sales under $0.5 million. As stated previously, these drug-level statistics refer to an individual 9-digit NDC.

Table 2 Characteristics of Drugs Involved in M&As, 2018–2023 ^[a]^

| Number of Target Company Drugs (Percent of All Target Company Drugs) | Number of Acquiring Company Drugs (Percent of All Acquiring Company Drugs)
Type of Compound
Small molecule, generic | 970 (65.0%) | 2,407 (90.8%)
Small molecule, brand | 447 (30.0%) | 189 (7.1%)
Original biologic, 351(a) | 75 (5.0%) | 40 (1.5%)
Biosimilar, 351(k) | 0 (0.0%) | 14 (0.5%)
Drug’s Annual IQVIA NSP Invoice Sales ^[b]^
<$0.5 million | 305 (29.0%) | 785 (42.5%)
$0.5–1 million | 160 (15.2%) | 354 (19.1%)
$1–5 million | 211 (20.1%) | 399 (21.6%)
$5–20 million | 179 (17.0%) | 191 (10.3%)
$20–100 million | 110 (10.5%) | 70 (3.8%)
>$100 million | 85 (8.1%) | 50 (2.7%)
Therapeutic Area
Central Nervous System | 335 (22.5%) | 485 (18.3%)
Dermatology | 181 (12.1%) | 8 (0.3%)
Pain Medication | 165 (11.1%) | 330 (12.5%)
Endocrine | 127 (8.5%) | 229 (8.6%)
Anti-infective | 117 (7.8%) | 296 (11.2%)
Cardiovascular | 116 (7.8%) | 423 (16.0%)
Gastrointestinal | 101 (6.8%) | 180 (6.8%)
Oncology | 88 (5.9%) | 306 (11.5%)
Hematology | 81 (5.4%) | 211 (8.0%)
Genitourinary | 42 (2.8%) | 55 (2.1%)
Immunomodulators | 39 (2.6%) | 28 (1.1%)
Other | 38 (2.5%) | 55 (2.1%)
Respiratory | 28 (1.9%) | 29 (1.1%)
Ophthalmology | 23 (1.5%) | 13 (0.5%)
Vaccines ^[c]^ | 11 (0.7%) | 2 (0.1%)

[a] Whereas Figure 4 presents company-level and M&A-level statistics covering all drugs and drug candidates from 2010–2023, this table presents drug-level statistics for prescription drugs marketed between 2018–2023 in our final drug sample. See Table B - 4 for cross tabulation of therapeutic area and brand status for all drugs in our dataset.

[b] Calculated based on all available IQVIA NSP sales in the year before the M&A.

[c] Coverage of vaccines is lower because many vaccine products are not sold through typical distribution channels (e.g., those purchased by the national stockpile) and may be missing at a higher rate. Vaccines are excluded from some analyses below, where explicitly noted.

Data source: IQVIA NSP

## 5.2 Change in Herfindahl-Hirschman Index

Figure 8 shows the change in annual HHI per therapeutic area^22^ over the study period, using harmonized company identifiers derived from historical records of drug ownership^23^. According to DOJ standards (U.S. Department of Justice, 2024), markets with HHIs over 1,800 are considered highly concentrated, markets with HHIs between 1,000 and 1,800 are considered moderately concentrated, and markets with HHIs below 1,000 are considered competitive (i.e., low concentration markets).^24^ Overall, we found that three markets were highly concentrated on average—anti-infectives, genitourinary, and ophthalmology. Five markets were moderately concentrated on average—immunomodulators, hematology, respiratory, endocrine, and gastrointestinal. Six markets were competitive on average—oncology, cardiovascular, dermatology, “other,” central nervous system, and pain medication.

Figure 8 Average Annual HHI, by Therapeutic Area

Note: Vaccines not shown because sales data are missing at a higher rate. The steep rise in genitourinary HHI is primarily due to large growth in sales of the drug Myrbetriq, manufactured by Astellas Pharma.

This graph shows the annual HHI from 2018 to 2023 by market. There are three panels, which group the markets based on high concentration, medium concentration, and low concentration. Among high-concentration markets, genitourinary has experienced the largest increase in HHI. All medium-concentration markets experienced a steady increase in HHI except for the market for respiratory drugs, which had a roughly constant HHI from 2018 to 2023, on average. Among the low-concentration markets, most had HHI change by a small number of points, though the cardiovascular drug market experienced a larger increase and the market for oncology drugs experienced a notable decrease.

Figure 9 shows how M&As during the study period are associated with market concentration one year after the merger or acquisition when defining markets by the 14 therapeutic areas.^25^ Across all M&As, the average change in HHI in the year following the M&A was +73 points (5.9 percent). Although we generally found greater market concentration after an M&A, this analysis does not account for other factors that may have occurred in the year following the M&A, including entry of new companies and products, changes in demand and patient population, and subsequent M&As. By far, the market that experienced the greatest consolidation was the market for genitourinary drugs, with an average HHI increase of 27.6 percent after an M&A (p = 0.0234). We also observed large HHI changes following an M&A in the market for gastrointestinal drugs (15.9 percent increase in HHI, on average, p = 0.0001), endocrine system drugs (12.2 percent increase, p < 0.0001), hematology drugs (13.5 percent increase, p < 0.0001), and cardiovascular drugs (11.4 percent increase, p = 0.0182). In two markets, oncology and ophthalmology medications, HHI was lower after the M&A, on average. Reductions in HHI could have occurred if drug companies used M&As to acquire approved drugs and enter those markets. Additionally, if new companies are also entering those markets, then this would tend to counteract the consolidating effects M&As may have.

M&As in highly concentrated markets such as genitourinary tended to produce larger increases in HHI (simple average increase of 171 points across highly concentrated markets) than moderately concentrated markets (average increase of 101 points) or competitive markets (average increase of 9 points). In percentage terms, however, the average increase was similar for high-concentration and medium-concentration markets (8.1 percent increase and 8.4 percent increase, respectively), but smaller for low-concentration markets (2.2 percent increase).

Figure 9 Mean HHI One Year Before and After M&A, by Therapeutic Area, 2018–2023 ^[a]^ [a] Higher HHI indicates greater market concentration. Error bars show one standard error in the mean, calculated as (standard deviation)/ sqrt(n) . A star indicates that the difference from pre to post is statistically significantly different from 0 (using a significance level of 0.05), according to the one-sample Wilcoxon test (p value shown on graph). Vaccines are not presented separately because there was only a single vaccine M&A in our drug-level sample. M&As between 2019–2022 were analyzed to ensure one full year of data when calculating HHI before and after the M&A. “Other” includes dietetics, vitamins and minerals, allergen tests, hospital solutions, and other categories classified by IQVIA as “other therapeutic class.” For data values, see Table B - 6.

This graph shows the mean change in HHI one year before an M&A compared to one year after the M&A. Most markets have small changes, by percentage. Almost all markets have an increase, on average, in HHI in the year following the M&A, but this graph does not account for other factors like new product launches, new companies entering those markets, companies exiting those markets, or other transactions that may have occurred during the one-year pre-M&A or post-M&A period. Data values are shown in Table B-3 in the Appendix.

## 5.3 Effects of M&As on Prices and Quantity Sold

We found that, after the M&A date, quantity sold decreased on average, both for drugs involved in an M&A and drugs not involved in an M&A.^26^ Generic drugs, however, experienced a greater decrease in quantity sold if they were involved in an M&A (see Figure 10).^27^ This downward effect became stronger over the two-year period we analyzed. In contrast, M&As were associated with slowing the decrease in quantity sold of brand drugs involved in the M&A, which was discernible both one year (p = 0.2445) and two years after the M&A (p = 0.0822) (see Figure 11 and Table B - 5).

In terms of price, brand drug prices increased after the M&A date, while generic drug prices decreased after the M&A date. At a high level, this trend was visible both for the WAC and the NSP price, and the direction of change was the same for M&A drugs and non-M&A drugs. For generics, though, prices dropped more slowly if the drug was involved in an M&A. This effect was visible for the NSP price at six months (p = 0.0097) and one year (p = 0.0069) but had dissipated by two years. Brand drugs showed less evidence of price changes. The WAC, though, had increased 1.5 percent faster for brands involved in M&As than for brands not involved in M&As at six months post-transaction (p = 0.0032).

Figure 10 Percent Change in Quantity Sold and Price for M&A vs. Non-M&A Drugs

[a] Brand drugs refer to any drug with a brand name, including original biologics and biosimilars.

[b] Pre-M&A values were measured over a one-year period that excluded the month of the M&A. A star indicates a strong statistical association, with significant difference between M&A and non-M&A drugs at a significance level of 0.05. See Table B - 5.

This graph shows the percent change in quantity sold, IQVIA NSP invoice price per extended unit, and WAC per extended unit, for generic drugs and brand drugs, comparing drugs involved in M&As to similar drugs not involved in M&As. Data values are in Table B-5 in Appendix B. After the M&A date, on average, generic drugs experienced a decrease in quantity sold and in both price metrics--both for M&A drugs and also for non-M&A drugs. After the M&A date, on average, brand drugs experienced a decrease in quantity sold but increases in both price metrics--both for M&A drugs and also for non-M&A drugs.

Figure 11 Effect of M&As on Changes in Quantity Sold and Price

[a] Brand drugs refer to any drug with a brand name, including original biologics and biosimilars.

[b] The effect is measured as (pre-to-post percent change for M&A drugs)/(pre-to-post percent change for non-M&A drugs) – 1, expressed as a percentage. Error bars show 95 percent confidence intervals, calculated using robust standard errors.

This graph shows the same information as the previous Figure 10, but the y-axis is the effect of M&As on the pre-to-post percent change in quantity sold, IQVIA NSP invoice price per extended unit, or WAC price per extended unit. Positive effects or y-values mean M&A drugs had less decrease or more increase in the specified quantity. Negative effects or y-values mean M&A drugs had more decrease or less increase in the specified quantity. M&As are associated with an upward effect on brand drugs’ quantity sold and a downward effect on generic drugs’ quantity sold. M&As are associated with an upward effect on generic drugs’ IQVIA NSP invoice price but no effect on brand drugs’ IQVIA NSP invoice price. M&As are associated with an upward effect on generic drugs’ WAC prices which grows over time and an upward effect on brand drugs’ WAC prices which decreases in strength over time.

## 5.4 M&As and Market Dynamics

### 5.4.1 Drugs in Shortage and M&As

As Table 3 shows, small molecule generics made up 81.5 percent of our sample (25,968 out of 31,873 total drugs) but 86.5 percent of the drugs that went into shortage (3,263 out of 3,772 total drugs). These drugs went into shortage more frequently between 2018–2023, with 12.6 percent of sampled small molecule generics going into shortage at some point during this period, compared to 6.8 percent of sampled original biologics and 9.2 percent of sampled small molecule brands. The number of new shortages of small molecules was highest in 2018 and 2019, when 1,207 and 1,000 of these drugs (i.e., 9-digit NDCs) went in shortage, respectively. Overall, though, there were more unique shortage events in 2018 (n=160) and 2023 (n=129) than in any other years in the study period.

Table 3 Shortage Frequency by Type of Drug, 2018–2023

Year | Number of Drugs in Sample that Went into Shortage, 2018–2023 ^[a]^ | | | | Number of Unique Shortage Events ^[c]^
Year | Original Biologics, Brand ^[b]^ | Small Molecule, Brand | Small Molecule, Generic | Total | Number of Unique Shortage Events ^[c]^
2018 | 7 | 101 | 1,207 | 1,315 | 160
2019 | 20 | 120 | 1,000 | 1,140 | 106
2020 | 1 | 103 | 614 | 718 | 103
2021 | 5 | 71 | 248 | 324 | 77
2022 | 13 | 74 | 362 | 449 | 91
2023 | 27 | 115 | 748 | 890 | 129
Total number of unique drugs that went into shortage between 2018–2023 ^[d]^ | 73 | 436 | 3,262 | 3,771 | 666
Total number of drugs marketed between 2018–2023 | 1,081 | 4,742 | 25,968 | 31,869 ^[e]^ | N/A
Percent of marketed drugs that went into shortage between 2018–2023 | 6.8% | 9.2% | 12.6% | 11.8% | N/A

N/A = not applicable.

[a] A drug is defined as a unique 9-digit NDC number.

[b] Original biologics include products approved through the 351(a) pathway, which excludes biosimilars. A column is not provided for biosimilars because no biosimilars in our sample went into shortage in 2018–2023.

[c] Defined as number of unique instances of a molecule-form-strength combination going into shortage.

[d] Total may be less than column sum because some drugs went into shortage in more than one year.

[e] The total number of drugs is 78 higher than the row sum because there were 78 biosimilars in our sample, none of which went into shortage.

Table 4 shows the proportion of drugs that went into shortage from 2018–2023, by therapeutic area. Drugs classified as “other” had the highest shortage rate, at 21.9 percent, followed by ophthalmology drugs (19.4 percent of drugs went into shortage from 2018–2023), gastrointestinal drugs (19.4 percent), pain medication (17.7 percent), and central nervous system drugs (15.6 percent). Among oncology drugs, 11.3 percent went into shortage at some point during the study period.

Table 4 Proportion with New Shortage, by Therapeutic Area and Related Characteristics, 2018–2023

Therapeutic Area ^[a]^ | Number in Sample that Went into Shortage from 2018–2023 | Total Number of Marketed Drugs in Sample from 2018–2023 | Proportion of Sample that Went into Shortage from 2018–2023 | Related Characteristics of Therapeutic Area
Therapeutic Area ^[a]^ | Number in Sample that Went into Shortage from 2018–2023 | Total Number of Marketed Drugs in Sample from 2018–2023 | Proportion of Sample that Went into Shortage from 2018–2023 | Mean Number of Sponsors per Molecule-Strength-Form ^[c]^ | Level of Concentration | Mean Annual HHI per Market ^[d]^ | Percent of Drugs in Therapeutic Area that are Generics | Average Annual Sales per Market (Billions) ^[e]^
Ophthalmology | 118 | 609 | 19.4% | 2.4 | High | 1,977 | 72.9% | $12.2
Gastrointestinal | 311 | 1,603 | 19.4% | 3.1 | Medium | 1,130 | 84.6% | $15.9
Pain Medication | 549 | 3,099 | 17.7% | 3.5 | Low | 501 | 86.4% | $17.0
Central Nervous System | 1,178 | 7,561 | 15.6% | 4.9 | Low | 466 | 88.1% | $67.8
Immunomodulators | 93 | 774 | 12.0% | 2.2 | Medium | 1,703 | 59.4% | $103.0
Oncology | 196 | 1,737 | 11.3% | 2.2 | Low | 752 | 67.5% | $82.8
Anti-infective | 329 | 3,048 | 10.8% | 3.1 | High | 3,312 | 86.7% | $41.4
Cardiovascular | 495 | 4,579 | 10.8% | 4.5 | Low | 675 | 88.9% | $19.2
Endocrine | 195 | 2,783 | 7.0% | 2.5 | Medium | 1,324 | 70.7% | $118.0
Respiratory | 31 | 772 | 4.0% | 2.5 | Medium | 1,431 | 78.6% | $39.0
Hematology | 27 | 1,954 | 1.4% | 3.1 | Medium | 1,410 | 72.1% | $45.2
Genitourinary | 6 | 705 | 0.9% | 5.0 | High | 3,093 | 88.2% | $4.8
Dermatology | 2 | 1,277 | 0.2% | 3.4 | Low | 612 | 81.2% | $6.8
Other ^[b]^ | 211 | 963 | 21.9% | 2.1 | Low | 514 | 71.4% | $6.4
All Therapeutic Areas | 3,772 | 31,837 | 11.8% | 3.3 | Medium | 1,374 | 81.6% | $39.7

[a] Vaccines are not presented as a line item because data are missing at a higher rate than in other therapeutic areas, but they are included in the overall total (“All Therapeutic Areas”).

[b] “Other” includes dietetics, vitamins and minerals, allergen tests, hospital solutions, and other miscellaneous categories classified by IQVIA as “other therapeutic class.”

[c] Mean was taken after calculating, on an annual basis, the number of unique drug sponsors that own the same molecule, strength, and dosage form.

[d] HHI was computed for each market, in each calendar year from 2018–2023.

[e] Calculated on an annual basis using IQVIA NSP sales.

Using the matched drug dataset, we compared the proportion of drugs that went into shortage within two years of the M&A date, both for M&A drugs and comparable non-M&A drugs.^28^ Overall, drugs involved in M&As had 24.3 percent higher odds of going into shortage within a two-year period than comparable drugs not involved in M&As (p = 0.0249) (see Figure 12). Generic drugs involved in M&As had 26.4 percent higher odds of going into shortage than comparable generic drugs that were not involved in an M&A (p = 0.0202). For the target company’s drugs, the odds of going into shortage within two years of an M&A were 2.265 times the odds for comparable non-M&A drugs (p < 0.0001), which corresponds to a 126.5 percent increase in the odds of going into shortage, but the 95 percent confidence interval around this point estimate was wide (64.7 to 211.7 percent increase). There was no evidence of brand drugs (p = 0.9453) or the acquirer’s drugs (p = 0.9906) going into shortage at a higher rate, as both odds ratios were very close to 1.0, with high p values.

In our sample, essential medicines had 13.6 percent higher odds of going into shortage in a two-year period if involved in an M&A, but the evidence for this finding was weaker, and a larger sample size would be needed to extrapolate beyond our sample (p = 0.5528). Interestingly, drugs sold in competitive markets had higher odds of shortage if involved in an M&A (p = 0.0055), whereas drugs sold in highly concentrated markets had lower odds of shortage if involved in an M&A (p = 0.0465). Drugs involved in transactions valued over $1 billion were substantially more likely to go into shortage within two years after the M&A than comparable non-M&A drugs; the confidence intervals for this finding were very wide, but the evidence for a nonzero difference compared to non-M&A drugs was nonetheless strong (p = 0.0198).

Figure 12 also presents odds ratios for various therapeutic areas and dosage forms. M&A drugs were associated with higher shortage risks than non-M&A drugs in the case of generic endocrine drugs (odds ratio = 4.05, p < 0.0001), generic central nervous system drugs (odds ratio = 1.87, p = 0.0003), and generic oral solids (odds ratio = 1.35, p = 0.0229). We also observed elevated shortage risks for generic gastrointestinal drugs (odds ratio = 1.63, p = 0.1871), generic cardiovascular drugs (odds ratio = 1.72, p = 0.1269), generic pain medications (odds ratio = 1.17, p = 0.5971), generic injectables (odds ratio = 1.22, p = 0.2341), and brand oral solid (odds ratio = 1.90, p = 0.1764)—though the evidence for these was weaker and larger sample sizes would be needed to generalize these results beyond our sample. As Figure 12 shows, some of the confidence intervals were wide in the subgroup analyses, particularly in cases where sample size was limited.

Figure 12 Odds Ratios of Shortage within 2 Years of M&A Date, 2018–2023 ^[a]^ [a] Odds ratio of 1 indicates that M&A drugs and non-M&A drugs have equal odds of going into shortage within two years of M&A date. The common odds ratios are calculated by stratifying on the groups that we used to match M&A drugs to non-M&A drugs, i.e., calendar month and year, brand status (brand vs. generic), molecule type (biologic vs. small molecule), dosage form, and subgroup price quintile. Brand drugs include biologics and biosimilars that are marketed with brand names. Differences between therapeutic areas may be partly due to differences in the ratio of generics to brands. Odds ratios computed as odds of going into shortage given that drug was involved in M&A divided by odds of going into shortage given that drug was not involved in M&A. Error bars show 95 percent confidence intervals. For complete data values, see Table B - 7.

This graph shows the odds ratio of going into shortage two years after the M&A date, for various drug groups. The odds ratio is equal to the odds of M&A drugs going into shortage divided by the odds of non-M&A drugs going into shortage. M&As were associated with elevated shortage risk for all drugs analyzed, generic drugs, the target company’s drugs, the target company’s generic drugs, drugs involved in transactions valued over 1 billion dollars, drugs in markets with low concentration, branded central nervous system drugs, generic endocrine drugs, and generic oral solid drugs. M&As were associated with lower shortage risk for drugs in high-concentration markets.

### 5.4.2 Essential Drugs and M&As

Using the full drug dataset of 31,837 drugs, we found that essential medicines listed on the ARMI EML had 11.6 percent higher odds of being involved in an M&A than non-essential medicines (p = 0.0307) (see Table 5). In our full drug sample, essential medicines on the ARMI EML made up 14.7 percent of the drugs involved in M&As during the study period, compared to 13.4 percent of drugs not involved in M&As during the study period. Essential medicines listed in the EO EML had 4.8 percent higher odds of being involved in an M&A, though the association was weaker (p = 0.3490).

Table 5 Frequency and Odds of being in an M&A, Essential and Non-essential Drugs, 2018–2023 ^[a]^

| EO EML ^[b]^ | | ARMI EML ^[c]^ | | Either EO or ARMI EML
| M&A ^[d]^ | Non-M&A ^[e]^ | M&A | Non-M&A | M&A | Non-M&A
Number of “non-essential” drugs not on designated EML | 3,018 | 23,883 | 3,067 | 24,468 | 3,017 | 23,868
Number of essential drugs on designated EML | 577 | 4,359 | 528 | 3,774 | 578 | 4,374
Percent that are on the designated EML | 16.1% | 15.4% | 14.7% | 13.4% | 16.1% | 15.5%
Odds of being essential | 0.1910 | 0.1830 | 0.1720 | 0.1540 | 0.1920 | 0.1830
Odds ratio ^[f]^ | 1.0475 (p = 0.3490) | | 1.1161 (p = 0.0307) | | 1.0454 (p = 0.3710)

[a] Counts of drugs refer to the number of 9-digit NDCs.

[b] The EO EML is the Executive Order Essential Medicines List published by FDA, which focuses on medicines treating both chronic and acute diseases.

[c] The ARMI EML is the list published by the Department of Health & Human Services’ (HHS) Office of the Assistant Secretary for Preparedness and Response and the Next Foundry for American Biotechnology at the Advanced Regenerative Manufacturing Institute, which focuses on essential medicines treating acute diseases.

[d] Number of drugs involved in an M&A at some point in the study period (2018–2023).

[e] Number of drugs not involved in an M&A at any point in the study period (2018–2023).

[f] Odds ratio calculated as odds of being involved in M&A given that the drug is essential divided by odds of being involved in M&A given that the drug is not essential. p value is for the test of equal odds.

In highly concentrated markets, essential medicines (as defined by the combined EO EML and ARMI EML) were significantly more likely to be involved in M&As between 2018 and 2023 than non-essential medicines (p = 0.0016; see Figure 13).^29^ In particular, essential medicines made up 34.1 percent of sample drugs involved in M&As, compared to 26.9 percent of sample drugs not involved in M&As. In low-concentration and medium-concentration markets, essential medicines were as likely to be involved in M&As as non-essential medicines.

Figure 13 Percent of Drugs that are Essential, by Market Concentration and M&A Involvement, 2018–2023

[a] Low, medium, and high market concentrations are defined as an HHI of <1,000, 1,000–1,8000, and >1,800, respectively. p values are for the two-sample test of equal proportions.

This graph shows the percent of marketed drugs that are essential, by market concentration and M&A involvement, for the period from 2018 to 2023. For low-concentration and medium-concentration markets, essential drugs were as likely to be involved in an M&A as they were to not be involved in an M&A from 2018 to 2023. In high-concentration markets, essential medicines were more likely to be involved in an M&A from 2018 to 2023 than not.

15 Of the 3,006 in-scope M&As in our 2010-2023 dataset, 1,794 (59.7 percent) had known transaction values. The annual rate of missing values ranged from 35.7 percent (in 2010) to 46.6 percent (in 2021), with a standard deviation of 3.3 percent.

16 “Homoscedasticity describes a situation in which the error term (that is, the “noise” or random disturbance in the relationship between the independent variables and the dependent variable) is the same across all values of the independent variables.” (Statistics Solutions, 2025)

17 DealForma classifies companies according to their highest-selling product. Target companies that make both brand drugs and generic drugs typically would be classified as brand drug companies, since generic drugs usually earn lower sales than brand drugs.

18 The relevant NAICS codes include:

- NAICS 325411–Medicinal and Botanical Manufacturing
- NAICS 325412–Pharmaceutical Manufacturing
- NAICS 325414–Biological Product (except Diagnostic) Manufacturing
- NAICS 541714–Research and Development in Biotechnology (except Nanobiotechnology)

19 As stated above, marketed drugs were identified as being “involved” in the M&A if (a) they were owned by the target and transferred to the acquirer; (b) they were brand drugs owned by the acquirer with a shared therapeutic area as one of the target drugs; or (c) they were generic drugs owned by the acquirer with a shared dosage form as one of the target drugs.

20 We use the term “biologics” to refer to both original biological products approved through the 351(a) pathway, and biosimilar biological products (also referred to as biosimilars) approved through the 351(k) pathway.

21 These findings differ from those in Figure 4F because DealForma categorizes a company with both brand and generic drugs on the market as brand if their asset with the highest dollar sales is a brand drug and generic if their highest revenue drug is generic.

22 Therapeutic class may be too broad or too narrow for defining a market, depending on the circumstances. When assessing mergers, DOJ and FTC use product substitutability to define markets of products that compete with each other (U.S. Department of Justice and the Federal Trade Commission, 2023). We use therapeutic class as an approximate definition of a pharmaceutical market given that the study is not focused on any one specific product. For more information on the challenges associated with defining pharmaceutical markets—including lack of product interchangeability, volume rebating, and product bundling—see Feldman et al. (2022).

23 In Figure 8, HHI was calculated for each calendar year, defining markets by their aggregate therapeutic classes. We used harmonized company identifiers because HHI involves calculating each company’s market share, which required harmonizing different versions of a single company name in the drug dataset.

24 HHI can be affected by factors other than consolidation of suppliers, including entry or emergence of high-selling products in an existing market. HHI may also depend on the total size of a therapeutic market. For example, a $10 billion market evenly divided across 10 suppliers has twice the HHI as a $20 billion market evenly divided across 20 suppliers.

25 See Table B - 6 for data values.

26 The quantity sold refers to the total mass in kg or total activity in IU of the active ingredient in the finished drug product that was sold.

27 The price of the drug after the M&A was calculated using the specified period of time. The price before the M&A was calculated using a one-year period. Only drugs with at least one full year of pre-M&A data were included in the sample.

28 As described previously, we compared the two drugs over the same calendar time. We matched M&A drugs to non-M&A drugs on the basis of calendar month and year, brand status (brand vs. generic), molecule type (biologic vs. small molecule), dosage form, and price quintile within drug groupings.

29 As in Section 5.2, markets are defined by broad therapeutic areas.