# 4 METHODOLOGY

We constructed three distinct analytic datasets by linking the data sources described in Section 4.1. Section 4.2 describes the inclusion criteria for our study, and Section 4.3 presents the analytic methods we used to answer the research questions.

## 4.1 Data Sources

Figure 1 provides an overview of the data sources we used in the analysis. A detailed description of each data source and the methods of assembling the analytic datasets appears in Appendices A.1 and A.2. Variables in bold indicate primary keys that uniquely identify rows of each dataset. The arrows represent the parent-child relationships, which correspond to the type of matching when joining datasets. For datasets that are periodically updated—including the Drug Shortages list, the National Drug Code (NDC) Directory, and the Orange and Purple Books—we used the Internet Archives to construct historical records (Internet Archive, 2024). This allowed us to (a) identify the complete list of drugs that went into shortage even if they have since been removed from the shortage list; (b) establish the correct ownership of drug applications at the time of the M&A; and (c) identify the full list of drugs (i.e., 9-digit NDCs) that were marketed under a drug application when the drug sponsor/applicant was involved in an M&A.

We used FactSet to identify in-scope M&As between pharmaceutical companies, DealForma for deal-related information, and Compustat for company financial information. We used IQVIA National Sales Perspective (NSP) for the quantity of drugs sold and prices. We used FDA Drug Shortage lists to identify drugs that went into shortage and shortage start dates, and the FDA NDC Directory to link NDC numbers to drug application numbers. We identified essential medicines based on both the Executive Order Essential Medicines List (EML) published by FDA and the EML published by the Department of Health & Human Services’ (HHS) Office of the Assistant Secretary for Preparedness and Response (ASPR) and the Next Foundry for American Biotechnology at Advanced Regenerative Manufacturing Institute (ARMI). To determine the owner of the drug application (i.e., “sponsor” or “applicant”), we combined the FDA Orange Book, the FDA Purple Book, and the Center for Biologics Evaluation and Research (CBER) list of New Drug Applications (NDAs) and Abbreviated New Drug Applications (ANDAs).

Where possible, datasets were merged on unique identifiers, such as NDC numbers, drug application numbers, and company Committee on Uniform Securities Identification Procedures (CUSIP) numbers. If a unique identifier was not available, we used name-based matching (e.g., product names, drug ingredient lists, company names). We did name-based matching using a combination of automated methods (e.g., exact matching, fuzzy matching, regex matching) followed by manual review.

Figure 1 Analytic Dataset Architecture (Entity-Relationship Diagram)

Variables in bold indicate primary keys, which uniquely identify rows of dataset.

[a] We pre-processed the drug shortage data to collapse from 11-digit NDC to 9-digit NDC, see Table A - 2.

[b] For full list of deal information, see Table A - 8.

[c] To aggregate across sales channels, we calculated total volume sales and weighted average prices per API unit and per extended unit, both in WAC dollars and in NSP invoice price dollars. For the full list of IQVIA-NSP drug characteristic variables, see Table A - 1.

[d] We de-duplicated cases where a single NDC had multiple entries in a given month-year. For the full list of drug characteristic variables, see Table A - 4.

[e] For full list of company financial variables, see Table A - 7.

[f] For full list of deal information, see Table A - 6.

[g] To acquire a single row per application number and month-year, we removed extraneous information relating to product number, supplements, etc., see Table A - 3.

[h] We merged the Executive Order EML with the ARMI EML and added an indicator for the EML source (EO, ARMI, or both) (see Table A - 5).

This figure shows that the following source data were used to construct the analytic datasets for the study: DealForma (which has data on M&A transactions, including company name and transaction details), FactSet (which also has data on M&A transactions, including company name and transaction details), Compustat (which has companies’ publicly available financial information), IQVIA National Sales Perspective (which has drug-level sales information), the FDA Drug Shortages list (which lists national shortages and identifies specific drugs by their NDC number), the FDA NDC Directory (which can be used to link the NDC numbers in the shortage postings to the drugs’ application numbers), the FDA Orange Book and Purple Book and CDER NDA/ANDA listings (which have information on the drug sponsors or companies), and the Essential Medicines Lists (which identify drugs that serve critical clinical functions). Each data source name links to a corresponding section in Appendix A.1 for further information.

To perform the analysis, we developed three distinct datasets.

■ M&A dataset (2010–2023). We identified 3,006 pharmaceutical M&As that were completed from 2010–2023 between companies that manufacture or develop drugs. We used this dataset to evaluate the frequency and type of pharmaceutical M&As, the value of these transactions, and the types of companies involved in these M&As.
■ Drug dataset (2018–2023). We developed a dataset of 31,837 unique 9-digit NDCs, which we refer to hereafter as “drugs.” We analyzed these drugs from 2018–2023, linking historical records of drug ownership, historical sales data, historical records of drug shortage announcements (including the specific drugs that went into shortage^11^), and essential medicine lists, which allowed us to assess trends in individual drugs before and after M&As. We used this dataset to evaluate the types of drugs involved in M&As (including whether they are designated as essential), the frequency and rate at which they went into shortage, and the effects of M&As on market concentration.
■ Drug cohort study dataset (2018–2023). We assigned 27,583 of the 31,837 drugs to one of two cohorts: a “treated” cohort of drugs that were involved in an M&A (n = 2,124) and a “control” cohort of drugs not involved in an M&A (n = 25,459). To assign drugs to their proper cohort, we used an exact matching algorithm. First, we partitioned the drug dataset (i.e., all 2,288,966 observations of the 31,837 drugs) into strata based on the month-year, price quintile, dosage form, brand/generic status,^12^ and molecule type (small molecule versus biologic). Then we identified strata that contained at least one drug that was involved in an M&A in the listed month-year and at least one drug that was marketed in that same month-year and had no M&As during the study period. We selected strata with at least one M&A drug and at least one non-M&A drug and included all observations in the selected strata. The resulting observations formed our drug cohort study dataset. We used this dataset to assess whether a drug’s price and quantity sold were different after an M&A compared to similar drugs not involved in an M&A. We also used the drug cohort study dataset to evaluate whether drugs involved in M&As had higher odds of going into shortage within two years of the M&A date. By matching on month and year, we were able to compare the M&A drugs to similar non-M&A drugs over the same periods of time. Matching on the other variables removed imbalances between the M&A drugs and the non-M&A drugs.

For our final dataset of in-scope pharmaceutical M&As, we merged FactSet, DealForma, and Compustat. For our final drug dataset, we merged all data sources in Figure 1 for the period 2018–2023. The drug cohort study dataset was selected from the drug dataset. Table 1 presents the characteristics of the drug dataset and the drug cohort study dataset.

Table 1 Sample Sizes of Drug Datasets ^[a]^

| Drug Dataset; (2018–2023) | | Drug Cohort Study Dataset; (2018–2023) ^[b]^
| Involved in M&A | Not Involved in M&A | Involved in M&A | Not Involved in M&A
Number of Observations ^[c]^ | 4,142 ^[d]^ | 2,284,824 | 2,506 | 168,511
Number of Drugs | 3,595 | 28,242 | 2,124 | 25,459
Number of M&As | 91 | | 61

N/A = not applicable.

[a] The full M&A dataset contained 3,006 M&As from 2010 to 2023. We matched 91 of these M&As to the prescription drugs marketed in the United States from 2018 to 2023.

[b] The 171,017 observations in the cohort study dataset were selected from the 2,288,966 observations in the full drug dataset.

[c] Shows the count of month-drug combinations involved in an M&A or not involved in an M&A. In the drug dataset, a single drug can be counted in both columns if it has data in a month when it was involved in an M&A and data in months when it was not involved in an M&A.

[d] There are more observations of M&As (4,142) than drugs involved in M&As (3,595) because a small percentage of drugs were involved in more than one M&A.

## 4.2 Inclusion Criteria

For the M&A dataset, we applied the following inclusion criteria:

■ The transaction event was completed between January 1, 2010, and December 31, 2023.
■ The transaction event is categorized as a merger, an acquisition of assets, or an acquisition of majority interest. We refer to all of these—mergers, acquisitions, asset transfers, divestitures—as M&As.
■ The acquiring company owned less than 50 percent of the target company before the transaction and at least 90 percent afterwards. The acquirer ownership percentage was reported in FactSet and served as the basis for this inclusion criterion.
■ The acquiring company had a primay or secondary North American Industry Classification System (NAICS) code of 325412, Pharmaceutical Manufacturing, or 325414, Biological Product (except Diagnostic) Manufacturing.
■ The target company had one or more of the following primary or secondary NAICS codes:
  ○ 325412—Pharmaceutical Manufacturing
  ○ 325414—Biological Product (except Diagnostic) Manufacturing
  ○ 325411—Medicinal and Botanical Manufacturing
  ○ 541714—Research and Development in Biotechnology (except Nanobiotechnology)
■ The target company in the transaction was not focused on cell/gene therapies, medical devices, or diagnostics. We identified these companies using the DealForma data.

For the drug dataset, we included prescription drugs marketed in the United States at any time between January 1, 2018, and December 31, 2023. When matching M&As to the drug-level data, we only included the M&As meeting the inclusion criteria above. While we did not exclude M&As based on company location,^13^ we only analyzed drugs marketed in the United States.

## 4.3 Analytic Methods

To answer the research questions, our study performed several analyses, which used different time periods based on data availability. The methods are described briefly below and are discussed in depth in Appendix A.3.

We used the dataset of 3,006 pharmaceutical M&As from January 2010 through December 2023 to analyze M&As by transaction value, type of deal, therapeutic area, technology, phase of development, drug type, company type, and company NAICS. Based on company type and NAICS, we evaluated trends in the specific pharmaceutical industries of the acquiring company and target company. We used the full drug dataset of 31,837 drugs from 2018–2023 to calculate descriptive statistics on the types of drugs involved in M&As, their annual sales, and their therapeutic areas. The full drug dataset also allowed us to calculate the HHI in the 12 months preceding and following each M&A, in order to assess changes in market concentration within markets defined by aggregate therapeutic areas.^14^ As part of our analysis of drug shortages, we used the full drug dataset to compare shortage rates within various drug subgroups (e.g., type of drug, therapeutic area). We also evaluated whether essential medicines are involved in M&As more frequently than drugs that are not listed in the EMLs, which we refer to as “non-essential medicines.” In our drug-level analysis, we define a drug at the level of the 9-digit NDC, which uniquely identifies the molecule, strength, dosage form, and labeler. Unless stated otherwise, all references to “drugs” refer to distinct 9-digit NDCs.

We used the drug cohort analysis dataset of 27,583 drugs from 2018 to 2023 to perform two retrospective cohort analyses comparing a cohort of drugs involved in M&As to a similar cohort of control drugs not involved in M&As. The two cohorts were matched on month and year so that they could be compared over the same calendar time. (See Appendix A.3 for a full description of all matching criteria.) In the first cohort analysis, we evaluated changes in price and quantity sold after the M&A date between the two cohorts. We considered two main price metrics, the NSP invoice price and the wholesale acquisition cost (WAC), both of which we calculated per extended unit, weighted by the quantity of drug sold. We measured the quantity of drug sold using total mass in kilograms (kg) or total activity in International Units (IU) of the API in the finished drug product. The NSP price provides insight into drug manufacturers’ sales price before accounting for off-invoice discounts. The WAC is the manufacturer’s list price, which often serves as a basis of negotiation for reimbursements paid by the payer or healthcare plan and therefore provides insight into how M&As are associated with changes in the cost to beneficiaries and plan sponsors.

In the second cohort analysis, we compared the two cohorts’ odds of going into shortage within two years of the M&A date. We selected a two-year period because an analysis by the Government Accountability Office (GAO) found that drugs that experienced a decrease in the number of suppliers in the prior two years were more likely to go into shortage (U.S. Government Accountability Office, 2016). This provides at least one theoretical mechanism that might explain associations found in this study, i.e., shortages occurring in the two-year period could plausibly be attributed to consolidating M&As. When identifying the drugs that went into shortage in a given month, we included any drugs listed in the FDA shortage announcement as well as any other drugs marketed at that time that had the same molecule-form-strength, since FDA declares shortages for the entire drug market.

All monetary values were inflated to 2023 dollars using the seasonally adjusted consumer price index for medical care (U.S. Bureau of Labor Statistics, 2024), including drug prices, drug sales data, M&A transaction values, and company financial information. Any values that were reported in foreign currency were converted to U.S. dollars using an exchange rate for the month when the data were reported (International Monteary Fund, 2024) before being inflated to 2023 dollars.

11 We note that, in this study, the definition of a “drug in shortage” is different from FDA’s definition of a shortage. Specifically, FDA lists a shortage by active ingredient; a single active ingredient may cover several NDCs accounting for different dosage forms. Consequently, the number of shortages as reported by FDA will differ from the number of shortages reported in this study.

12 We used IQVIA NSP to identify the brand/generic status of each drug. In general, drugs are marked as brands if they are sold under a brand name, which includes original biologics and biosimilars sold under brand names. Drugs are marked as generic if they are not sold under a brand name, which could include drugs like “water for injection.”

13 The pharmaceutical industry is highly global and excluding companies on the basis of geographic location would have been too restrictive given that many non-U.S. companies operate in the U.S. drug market.

14 HHI is a measure of market concentration. We used it to assess consolidation and levels of competition before and after an M&A. We defined drug markets by therapeutic area. See Appendix A.3.5 for how HHI is calculated.