# 3 EXISTING RESEARCH ON M&As IN THE PHARMACEUTICAL SECTOR

## 3.1 Trends in M&As

Gagnon and Volesky (2017) studied the rise of M&As in generic drug markets from 1995 to 2016. Using data from Bloomberg Finance L.P., they found 345 M&As completed in those years that had a target company classified as a “generic medical drug company.”^10^ Of these M&As, 122 (35.3 percent) involved target companies based in the United States. Among the deals targeting companies based in the United States, M&A activity increased after 1995 and spiked in 2014 and 2015. They found no M&As targeting U.S. generic drug companies in 1995, and only seven such M&As in 2014 (with a total announced value of $0.89 billion). By 2015, there were 16 such M&As totaling $26.66 billion, and in 2016 there were 17 M&As totaling $42.95 billion. These high transaction prices suggest that many of those generic drug company targets are relatively large, making M&As a strategy for substantial growth among acquiring companies that market generic drugs or are entering these markets. The high dollar value of M&As between 2015 and 2016 was in part due to Teva’s acquisition of Allergan’s generic drug business for $40.5 billion, accounting for 89.8 percent of the total M&A value in 2016 involving U.S. target companies (Teva Pharmaceuticals, 2015; Gagnon & Volesky, 2017). Bansal et al. (2018) attribute another spike in pharmaceutical M&A activity in 2018 to U.S. tax reform that went into effect in late 2017, which provided tax cuts to targets of M&A. Bansal et al. found that pharmaceutical transactions increased from 151 M&As in 2017 to 212 M&As in the first six months of 2018 alone, totaling over $200 billion in transaction value.

Several authors have concluded that the characteristics of companies’ drug portfolios affect the incidence of M&A transactions. Hammoudeh and Nain (2024) found that companies with portfolios of drugs in the same therapeutic area(s) are more likely to merge. Similarly, Bena and Li (2014) reported that companies with “technological overlap,” including companies having comparable patent portfolios and technical knowledge bases, are more likely to merge. In contrast, Feng et al. (2023) studied M&As in the United States involving on-patent drugs between 2007 to 2019 and found that just 25 percent of deals in their sample involved companies that made drugs in the same therapeutic area. It was far more common during their period of analysis for acquisitions to involve companies whose drugs did not compete in the same therapeutic area.

One way authors assess the types of drugs transferred in M&As is by evaluating the proportion of total M&A transaction value associated with certain drug types. A report released by GlobalData (2024) found that orphan drugs for rare diseases accounted for 36 of the announced M&As in the first quarter of 2024, accounting for $17 billion out of $65 billion (26.2 percent) total value of pharmaceutical M&As. Using a similar method, Gagnon and Volesky (2017) found that generic drug target companies accounted for 9.8 percent and 8.6 percent of all completed M&As with pharmaceutical targets based inside the United States and outside the United States, respectively, between 1995 to 2016.

## 3.2 Effects of M&As on Drug Prices and Quantity Sold

According to the literature, the impacts of pharmaceutical M&As on drug prices and quantity sold depend on the price metric being used and the drug’s characteristics—including whether the acquirer and target have drugs that compete with each other (e.g., as indicated by the drugs treating the same indications or having the same therapeutic areas). Bonaime and Wang (2024) studied Medicaid-covered outpatient drug products using prices reported in the National Average Drug Acquisition Cost (NADAC) survey. They found that, when the target and acquirers’ drugs had similar therapeutic areas, the M&A was followed by an average increase of 2.2 percent in the NADAC price of the acquirer’s drugs. This effect, however, lasted for about one year. Feng et al. (2023) analyzed 151 M&As between 2007 and 2019 and observed much larger changes in manufacturers’ net prices when the M&A was not required to be disclosed to DOJ or FTC because the deal valuation was below $200 million. These undisclosed M&As were associated with large average increases in the net price of drugs with indications common to both the acquirer and the target. The average increases were 270 percent for the target company’s drugs and 63 percent for the acquiring company’s drugs.

In contrast, similar M&As above the reporting threshold were associated with a more modest average price increase of 11 percent shortly after the transaction. No price increase was observed, on average, for “diversifying” acquisitions by large pharmaceutical companies that were acquiring drugs in nonoverlapping therapeutic areas. The authors concluded that regulatory review and government oversight help maintain competition in U.S. drug markets.

Schutz (2023) analyzed branded drug companies and found that M&As led to net price increases of 19 percent after the transaction. They also found that a net price increase was most common when the target and acquiring companies had overlapping therapeutics portfolios. Hammoudeh and Nain (2024) similarly found that brand drugs’ pre-rebate prices increased after a merger.

According to the literature, M&As may also affect drug prices because of their role in market consolidation. Several authors found reduced market competition to be a factor in rising drug prices and supply shortages. Gagnon and Volesky (2017) argue that, by nature, M&As tend to decrease the number of competing firms. Gupta et al. (2019) agreed; their analysis of generic drugs suggests that a decrease in the number of generic suppliers—and thus a decrease in the number of available generic substitutes for a given brand drug—is associated with increasing prices of generic drugs. Schutz (2023) found that M&As lead to price increases for brand drugs as well; this was true for brand drugs with overlapping therapeutic areas between the two parties in the M&A, and it was also true regardless of market concentration, i.e., whether there was a single product dominating the market. Hammoudeh and Nain (2024) similarly found that, after an M&A, highly innovative companies (defined as those generating the majority of their revenue from novel, first-in-class drugs) tended to raise pre-Medicaid-rebate prices of drugs with therapeutic areas shared by both M&A parties, especially in the case of first-in-class patented brands.

However, different patterns have been observed for other drug groups. Hammoudeh and Nain (2024) found that generic drugs tend to experience declining prices after an M&A due to gains in efficiency, reductions in cost, and reallocating research and development (R&D) spending to cheaper, lower-risk products. While this differs from the findings of Gupta et al. (2019), the study by Hammoudeh and Nain (2024) was based on pre-Medicaid-rebate drug prices paid by state Medicaid agencies, which they calculated using CMS’s State Drug Utilization Data.

## 3.3 Impact of M&As on Drug Shortages

Based on a 2023 analysis by the U.S. Food & Drug Administration (FDA), new drug shortages peaked in 2011 and then rapidly declined over the next few years, but since 2015, the number of new drug shortages per year has steadily increased (U.S. Food & Drug Administration, 2023). The same analysis found that, between 2017 and 2023, the number of annual ongoing drug shortages also increased. Sterile injectables make up the majority of shortages. FDA analyzed a sample of 127 drug shortages in 2010 and 2011 and found that 80 percent were sterile injectables (U.S. Food & Drug Administration, 2011). In another analysis from 2020, FDA sampled 163 drugs that went into shortage between 2013 and 2017 and found that 63 percent were sterile injectables (U.S. Food and Drug Administration, 2020).

While there is limited research on the impact of M&As on drug shortages, two main contributing factors are often identified—vulnerabilities in the pharmaceutical supply chain and limited domestic manufacturing capacities. There is debate among authors, however, about whether growing market concentration increases supply chain vulnerabilities. Gagnon and Volesky (2017) note that market competition tends to decrease following an M&A, which may partially explain the increasing number of shortages during their study period from 1995 to 2016. While a causal analysis is beyond the scope of Gagnon and Volesky’s study, a possible explanation for their observations is that undiversified supply chains have increased risk for drug shortages, and reduced competition from M&As heightens this risk (U.S. Department of Health and Human Services, 2024). In the United States, most of the injectable generic drugs on the market were supplied by only seven manufacturers as of 2016 (World Health Organization, 2016). The high degree of consolidation may be partly responsible for recent shortages in injectable generic oncology drugs, which have an especially high public health impact due to the heavy reliance of cancer patients undergoing chemotherapy on those drugs (U.S. Food and Drug Administration, 2020).

Haninger et al. (2011), however, offer an alternative view. They found that market consolidation in the sterile injectable industry was relatively rare between 2005 and 2011. They concluded that M&As were not a factor in shortages of sterile injectable drugs during that time and suggested instead that manufacturing capacities were misaligned with demand. Specifically, they pointed to a sudden increase in use of chemotherapy, driven in part by expiration of numerous chemotherapy drug patents expiring between 2008–2010.

Generic drugs are especially vulnerable to supply shortages and experienced high-profile shortages in the early 2010s (Schweitzer, 2013), which have continued in recent years (Joyce, 2023). Generic drugs often have low profit margins, and sterile injectables generally require large financial investments due to complex and highly specialized production technologies. This limits manufacturers’ profitability and disincentivizes market entry, leading to fewer suppliers in those drug markets (U.S. Department of Health and Human Services, 2024). Additionally, there are periods of extreme concentration in the U.S. generic drug markets. In 2020, FDA reported that 40 percent of generic drug markets had only a single manufacturer supplying the market (U.S. Food and Drug Administration, 2020). Without other suppliers to help meet unexpected supply shortfalls or demand surges, a single disruption may be sufficient to trigger a shortage.

We did not identify any studies that quantify the effects of M&As on drug shortages, but there is significant literature on how shortages are caused by supply chain vulnerabilities, which M&As may precipitate. For example, some authors have suggested that M&As impact manufacturing practices, leading to consolidation of product lines, product discontinuations, or relocation of manufacturing facilities abroad—all of which can reduce supply chain resiliency and increase the risk of drug shortages (The Multi-Stakeholder Steering Committee On Drug Shortages In Canada, 2017; Gagnon, 2012; Gagnon & Volesky, 2017). A report by FDA (2020) points to manufacturing and product quality problems as the primary reasons for disruptions in production and supply, accounting for 62 percent of all drug shortages. While M&As were not the focus of this FDA report, some of the quality problems may have followed an M&A (e.g., brought on by a product discontinuation or product line consolidation). Additionally, over the past three decades, pharmaceutical manufacturing has become increasingly global. This limits the nation’s options in responding to some supply chain disruptions and the timeliness of responses, because changes that increase manufacturing output (e.g., repurposing a facility to make the drug in shortage) may trigger regulatory review by multiple other governments. As of August 2024, 52 percent of all FDA-registered finished dosage form (FDF) manufacturing facilities and 76 percent of all FDA-registered active pharmaceutical ingredients (API) manufacturing facilities were outside the United States (National Economic Council, National Security Council, 2024). The percentage of FDA-registered manufacturers making FDFs and APIs is even higher among generics, with 54 percent of generic FDF manufacturers and 82 percent of generic API manufacturers being located internationally. While global manufacturing does offer economic benefits, it also increases the complexity of supply chains, which may limit the United States’ ability to respond to supply chain risks and disruptions.

10 This likely excludes many companies that make brand drugs. Many companies that make both brands and generics would be classified as brand drug companies because brand drug sales generally surpass generic drug sales.