# 2 STUDY OBJECTIVES

The primary objectives of this study are to (1) assess trends in pharmaceutical M&As over the 2010–2023 period, (2) evaluate characteristics of drugs involved in M&As, and (3) examine the effects of M&As on the pharmaceutical supply chain. The primary metrics we apply to measure these effects are price, volume (or quantity) of the drug sold, market concentration (using Herfindahl-Hirschman Index scores), and a drug’s odds of going into shortage. Specifically, we aim to answer the following research questions:

1. How many pharmaceutical M&As occurred between 2010–2023? Has the frequency of M&As shown an identifiable trend during these years?
2. What are the characteristics of the companies and products involved in pharmaceutical M&As? What are the main therapeutic areas, drug technologies^8^, and development stages^9^ of the drug assets targeted by M&As? What types of drugs, company ownership structures (publicly held or private), and sizes of companies are typical of M&A acquiring companies and target companies?
3. Are M&As associated with a change in drug prices or the quantity of drugs sold (as measured through the quantity of active pharmaceutical ingredient in the finished drug product that is sold)?
4. How do M&As affect the pharmaceutical supply chain?
  a. Are M&As followed by changes in market concentration, as measured by the Herfindahl-Hirschman Index (HHI)?
  b. Do M&As increase the odds of a drug going into shortage?

This study advances the literature in several ways. We identified a total of 3,006 pharmaceutical M&As across the 14-year period 2010–2023, and 31,837 unique drugs that were marketed in the United States between 2018–2023. In addition to providing new findings about the associations between M&As and drugs prices and quantities sold, we also present a stratified cohort analysis of the effects of M&As on a drug’s odds of going into shortage within two years of the M&A date, with subgroup analyses for particularly high-risk drug groups, such as generics and essential medicines. To our knowledge, this is the first study designed to quantify the association between M&As and drug shortages.

8 Drug technologies were identified using the corresponding variable in the DealForma database, which defines drug technology as the branch of pharmaceutical manufacturing of the primary asset in the M&A deal. We aggregated this variable and options include small molecules, biologics, dosage form technology, or other (e.g., genomics, microarrays, compound libraries).

9 Development stages refer to the major steps in bringing a new drug to market, including drug discovery, preclinical testing, phase I testing, phase II testing, phase III testing, and marketing after receiving approval.