# 1 INTRODUCTION

In the last two decades, there has been much consolidation in the U.S. pharmaceutical industry (Richman, et al., 2017), largely due to mergers and acquisitions (M&As). Pharmaceutical M&As and drug shortages have been important focus areas for researchers, the healthcare industry, and federal agencies in recent years. For example, in a 2022 workshop jointly organized by the Federal Trade Commission (FTC) and Department of Justice (DOJ), it was noted “that the median list price for new drugs has been increasing in recent years, that ‘killer’ acquisitions shut down potential competitors, and that lawsuits have been alleging illegal bundling and tying practices in the industry” (U.S. Federal Trade Commission, 2022). In healthcare markets, the stakes are often life-or-death, with many millions of people relying on pharmaceuticals to treat or manage diseases and health conditions, or for preventative care. There is potential for pharmaceutical M&As to be followed by drug price increases, lower patent output (a potential sign of diminished innovation), issues with manufacturing quality, and diminished drug availability (U.S. Federal Trade Commission, 2022).

Recent studies have reported mixed findings about the effects of M&As on pharmaceutical markets, including on drug prices and the quantities of drug sold. Hammoudeh and Nain (2024) found that M&As in the pharmaceutical sector have a negligible effect on drug prices, but other studies concluded that M&As are associated with price increases (Gupta, et al., 2019; Schutz, 2023; Bonaime & Wang, 2024). Several authors identify specific market characteristics that relate to different pricing effects in the wake of M&As, including drug type (Fein, 2024; Schutz, 2023; Hammoudeh & Nain, 2024), level of market concentration (Chintan, et al., 2017; Schutz, 2023; Bonaime & Wang, 2024; Gagnon & Volesky, 2017; Gupta, et al., 2019), and overlapping therapeutic areas between the target and acquirer’s drug portfolios (Schutz, 2023; Bonaime & Wang, 2024; Hammoudeh & Nain, 2024).

Few studies have examined the effect of M&As on supply chain vulnerabilities and drug shortages, although these are areas of serious concern to policymakers. Gagnon (2012) concluded that M&As often lead to decisions that affect drug supply chains, such as reducing product lines, discontinuing products altogether, or changing manufacturing practices. Any of these can result in supply shortages. Most drug shortages in the United States affect generics (The White House, 2021), and a 2017 study found M&As to be steadily rising in the generic drug industry since 1995, with a surge in 2015 (Gagnon & Volesky, 2017). It is therefore of interest to understand whether and how M&As are associated with risks of drug shortages, supply disruptions, and price changes. The nature and extent of such associations are likely to be highly relevant to the U.S. drug market given their potential effects on national drug expenditures and patient health.