# APPENDIX B SUPPLEMENTAL TABLES

Table B - 1 M&As by Year and Transaction Type, 2010–2023

Year | Type of Transaction
Year | Acquisition | Divestiture/Asset Purchase ^[a]^ | Merger | Unknown | Total
2010 | 77 | 60 | 3 | 56 | 196
2011 | 78 | 68 | 2 | 57 | 205
2012 | 59 | 70 | 0 | 45 | 174
2013 | 70 | 77 | 1 | 62 | 210
2014 | 90 | 68 | 4 | 69 | 231
2015 | 99 | 100 | 1 | 66 | 266
2016 | 93 | 98 | 4 | 72 | 267
2017 | 76 | 83 | 8 | 47 | 214
2018 | 76 | 66 | 5 | 67 | 214
2019 | 66 | 66 | 10 | 53 | 195
2020 | 85 | 54 | 8 | 57 | 204
2021 | 110 | 54 | 7 | 67 | 238
2022 | 76 | 65 | 2 | 67 | 210
2023 | 80 | 52 | 8 | 42 | 182
Total | 1,135 | 981 | 63 | 827 | 3,006
Percent of Total with Known Type | 52.1% | 45.0% | 2.9% | N/A | 100.0%
p value ^[b]^ | 0.3188 | 0.6753 | N/A | N/A | N/A

N/A = not applicable.

[a] “Divestiture/asset purchase” includes business unit purchases and platform/product purchases.

[b] p value calculated from Augmented Dickey-Fuller test for stationarity.

Table B - 2 Average Annual M&A Transaction Values, 2010–2023

Year | Transaction Value (Million 2023 $)
Year | Average | SD | Median | IQR | Sample Size
2010 | 594.55 | 1,667.16 | 66.79 | 380.71 | 126
2011 | 524.79 | 1,919.65 | 55.03 | 359.15 | 131
2012 | 578.59 | 1,683.74 | 58.87 | 386.58 | 103
2013 | 500.39 | 1,662.96 | 61.93 | 299.96 | 124
2014 | 932.59 | 3,048.56 | 124.06 | 571.53 | 144
2015 | 1,938.97 | 7,335.41 | 162.48 | 896.49 | 162
2016 | 1,096.83 | 5,054.10 | 73.18 | 438.46 | 164
2017 | 746.50 | 3,224.58 | 81.15 | 447.31 | 120
2018 | 464.34 | 1,379.77 | 37.98 | 204.50 | 124
2019 | 2,557.12 | 12,753.61 | 86.19 | 505.83 | 120
2020 | 1,617.24 | 8,384.77 | 79.39 | 512.63 | 126
2021 | 980.51 | 3,943.49 | 97.35 | 502.61 | 127
2022 | 627.74 | 1,696.66 | 108.77 | 394.04 | 115
2023 | 1,327.72 | 4,963.52 | 86.04 | 436.34 | 108
p value ^[a]^ | 0.0387 | N/A | 0.2338 | N/A | N/A

[a] p value calculated from Augmented Dickey-Fuller test for stationarity. p values not computed for standard deviation (SD), interquartile range (IQR), or sample size.

Table B - 3 M&As by Type, 2010–2023

| Number of M&As
| 2010 | 2011 | 2012 | 2013 | 2014 | 2015 | 2016 | 2017 | 2018 | 2019 | 2020 | 2021 | 2022 | 2023 | Total | % of Total
Transaction Value (Million 2023 USD)
<$5M | 17 | 18 | 19 | 22 | 15 | 14 | 22 | 10 | 31 | 18 | 16 | 14 | 10 | 14 | 240 | 13%
$5–25M | 17 | 32 | 20 | 28 | 31 | 26 | 33 | 21 | 21 | 21 | 27 | 23 | 19 | 17 | 336 | 19%
$25–100M | 35 | 28 | 17 | 18 | 23 | 30 | 40 | 33 | 26 | 24 | 23 | 27 | 24 | 24 | 372 | 21%
$100–500M | 32 | 28 | 23 | 34 | 35 | 41 | 31 | 28 | 21 | 26 | 28 | 29 | 40 | 27 | 423 | 24%
>$500M | 25 | 25 | 24 | 22 | 40 | 51 | 38 | 28 | 25 | 31 | 32 | 34 | 22 | 26 | 423 | 24%
Target Company Primary Therapeutic Area (When Applicable) ^[a]^
Oncology | 11 | 13 | 7 | 12 | 13 | 15 | 18 | 12 | 15 | 15 | 19 | 23 | 17 | 17 | 207 | 25%
Central Nervous System | 8 | 8 | 6 | 7 | 13 | 14 | 9 | 6 | 3 | 8 | 15 | 10 | 8 | 12 | 127 | 15%
Anti-infective | 9 | 12 | 8 | 6 | 14 | 16 | 11 | 11 | 9 | 3 | 5 | 5 | 9 | 5 | 123 | 15%
Immunomodulators | 7 | 3 | 7 | 2 | 5 | 3 | 4 | 4 | 5 | 2 | 5 | 8 | 3 | 9 | 67 | 8%
Endocrine | 6 | 5 | 5 | 3 | 1 | 5 | 4 | 5 | 4 | 3 | 8 | 6 | 0 | 8 | 63 | 8%
Dermatology | 2 | 5 | 4 | 4 | 4 | 3 | 8 | 1 | 1 | 5 | 5 | 4 | 5 | 3 | 54 | 6%
Ophthalmology | 0 | 1 | 1 | 2 | 6 | 1 | 2 | 2 | 3 | 2 | 3 | 1 | 4 | 4 | 32 | 4%
Other | 2 | 4 | 4 | 1 | 1 | 4 | 1 | 2 | 2 | 4 | 1 | 2 | 2 | 1 | 31 | 4%
Cardiovascular | 1 | 1 | 1 | 3 | 2 | 2 | 2 | 5 | 2 | 2 | 2 | 2 | 4 | 1 | 30 | 4%
Gastrointestinal | 2 | 3 | 3 | 3 | 3 | 3 | 1 | 1 | 1 | 3 | 1 | 0 | 1 | 2 | 27 | 3%
Genitourinary | 3 | 1 | 0 | 1 | 3 | 3 | 1 | 1 | 4 | 2 | 1 | 1 | 1 | 5 | 27 | 3%
Hematology | 3 | 2 | 2 | 1 | 2 | 1 | 2 | 0 | 1 | 3 | 4 | 2 | 3 | 1 | 27 | 3%
Respiratory | 0 | 1 | 0 | 1 | 2 | 2 | 1 | 1 | 0 | 2 | 4 | 2 | 2 | 2 | 20 | 2%
Target Company Primary Technology (When Applicable) ^[a]^
Small Molecule | 30 | 42 | 30 | 23 | 45 | 44 | 29 | 25 | 22 | 27 | 40 | 31 | 34 | 38 | 460 | 53%
Biologic | 15 | 8 | 10 | 12 | 19 | 18 | 21 | 12 | 14 | 16 | 28 | 30 | 16 | 26 | 245 | 28%
Formulation | 5 | 9 | 6 | 8 | 2 | 4 | 4 | 2 | 5 | 6 | 5 | 5 | 2 | 0 | 63 | 7%
Other | 5 | 3 | 4 | 4 | 4 | 9 | 10 | 7 | 8 | 9 | 6 | 12 | 7 | 5 | 93 | 11%
Type of Deal
Acquisition | 77 | 78 | 59 | 70 | 90 | 99 | 93 | 76 | 76 | 66 | 85 | 110 | 76 | 80 | 1,135 | 52%
Asset Transfer/Divestiture | 60 | 68 | 70 | 77 | 68 | 100 | 98 | 83 | 66 | 66 | 54 | 54 | 65 | 52 | 981 | 45%
Merger | 3 | 2 | 0 | 1 | 4 | 1 | 4 | 8 | 5 | 10 | 8 | 7 | 2 | 8 | 63 | 3%
Phase of Development of Highest-Value Asset of Target Company
Platform / Discovery | 4 | 5 | 1 | 2 | 1 | 5 | 8 | 6 | 4 | 2 | 12 | 8 | 8 | 3 | 69 | 3%
Preclinical / IND | 5 | 4 | 4 | 5 | 10 | 4 | 9 | 7 | 5 | 9 | 4 | 9 | 11 | 11 | 97 | 4%
Phase I | 5 | 3 | 2 | 5 | 8 | 7 | 6 | 3 | 9 | 2 | 11 | 11 | 3 | 6 | 81 | 4%
Phase II | 12 | 12 | 13 | 8 | 13 | 12 | 11 | 8 | 13 | 14 | 19 | 13 | 6 | 16 | 170 | 8%
Phase III | 8 | 6 | 4 | 6 | 3 | 7 | 12 | 8 | 9 | 10 | 12 | 11 | 7 | 9 | 112 | 5%
Approved | 22 | 27 | 19 | 21 | 38 | 35 | 21 | 17 | 17 | 20 | 18 | 13 | 21 | 20 | 309 | 14%
Not Disclosed | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0%
Not Applicable | 7 | 11 | 10 | 8 | 11 | 10 | 10 | 14 | 8 | 11 | 8 | 26 | 8 | 7 | 149 | 7%
Highest-Value Asset of Target Company
Biosimilar | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0%
Brand | 30 | 30 | 29 | 24 | 41 | 55 | 45 | 12 | 9 | 27 | 33 | 29 | 29 | 7 | 400 | 18%
Generic | 5 | 6 | 6 | 4 | 5 | 8 | 4 | 1 | 1 | 1 | 1 | 2 | 1 | 0 | 45 | 2%
OTC | 3 | 6 | 5 | 2 | 2 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 0 | 0 | 22 | 1%

[a] The target company’s primary therapeutic area and primary technology were identified using DealForma, which was only available for M&As that successfully matched to DealForma.

Table B - 4 Counts of All Drugs in 2018–2023 Drug Dataset, by Therapeutic Areas and Brand Status

Therapeutic Area | Number of Marketed Prescription Brand Drugs in Sample, 2018–2023 | Number of Marketed Prescription Generic Drugs in Sample, 2018–2023
Anti-infective | 406 | 2,642
Cardiovascular | 509 | 4,070
Central nervous system | 903 | 6,657
Dermatology | 240 | 1,037
Endocrine | 816 | 1,967
Gastrointestinal | 247 | 1,356
Genitourinary | 83 | 622
Hematology | 545 | 1,409
Immunomodulator | 314 | 460
Oncology | 565 | 1,172
Ophthalmology | 165 | 444
Other | 275 | 688
Pain | 420 | 2,679
Respiratory | 165 | 607
Vaccine | 212 | 164

Table B - 5 Changes in Price and Quantity Sold for M&A Drugs versus Non-M&A Drugs

Metric | Brand Status | Post-M&A Period ^[a]^ | Mean Percent Change ^[b]^ | | Mean Effect of M&A on Pre-to-Post Change ^[c]^ | Robust p value ^[d]^
Metric | Brand Status | Post-M&A Period ^[a]^ | M&A Drugs | Non-M&A Drugs | Mean Effect of M&A on Pre-to-Post Change ^[c]^ | Robust p value ^[d]^
Quantity Sold | Brand | 1–6 months | −15.7% | −13.6% | −0.024 (−0.113, 0.065) | 0.5988
Quantity Sold | Brand | 1–12 months | −10.9% | −15.6% | 0.056 (−0.037, 0.146) | 0.2445
Quantity Sold | Brand | 13–24 months | −24.4% | −31.9% | 0.110 (−0.013, 0.222) | 0.0822
Quantity Sold | Generic | 1–6 months | −24.3% | −19.0% | −0.066 (−0.131, −0.006) | 0.0320
Quantity Sold | Generic | 1–12 months | −25.4% | −18.7% | −0.082 (−0.148, −0.024) | 0.0069
Quantity Sold | Generic | 13–24 months | −41.2% | −32.9% | −0.124 (−0.269, 0.004) | 0.0562
NSP Price per Extended Unit | Brand | 1–6 months | 2.2% | 1.7% | 0.005 (−0.013, 0.023) | 0.5762
NSP Price per Extended Unit | Brand | 1–12 months | 1.0% | 1.9% | −0.009 (−0.028, 0.009) | 0.3254
NSP Price per Extended Unit | Brand | 13–24 months | 3.6% | 3.6% | 0.000 (−0.027, 0.027) | 0.9929
NSP Price per Extended Unit | Generic | 1–6 months | −3.1% | −5.2% | 0.021 (0.005, 0.037) | 0.0097
NSP Price per Extended Unit | Generic | 1–12 months | −4.4% | −6.6% | 0.024 (0.006, 0.040) | 0.0069
NSP Price per Extended Unit | Generic | 13–24 months | −12.2% | −12.0% | −0.002 (−0.042, 0.037) | 0.9043
WAC per Extended Unit | Brand | 1–6 months | 3.7% | 2.1% | 0.015 (0.005, 0.025) | 0.0032
WAC per Extended Unit | Brand | 1–12 months | 3.4% | 2.7% | 0.007 (−0.004, 0.018) | 0.1949
WAC per Extended Unit | Brand | 13–24 months | 4.9% | 5.1% | −0.002 (−0.028, 0.024) | 0.8810
WAC per Extended Unit | Generic | 1–6 months | −4.0% | −4.6% | 0.006 (−0.006, 0.019) | 0.3318
WAC per Extended Unit | Generic | 1–12 months | −4.6% | −5.6% | 0.011 (−0.003, 0.025) | 0.1157
WAC per Extended Unit | Generic | 13–24 months | −10.0% | −11.9% | 0.022 (−0.005, 0.048) | 0.1139

[a] Both the post-M&A period and the pre-M&A period excluded the month of the M&A. The pre-M&A period included the 12 months prior to the M&A.

[b] The mean percent change was estimated as ∆price = ln(average value in post-M&A period / average value in pre-M&A period). The mean value of ∆price was estimated from a linear model regressing ∆price on M&A status and matching group. Final estimates of percent change were transformed out of the logarithmic scale: mean percent change = 100% × [exp(mean value of ∆price) – 1].

[c] The effect is the average percent change in ∆price for M&A drugs compared to non-M&A drugs. For example, in the first row, the average effect is approximately (−0.157 + 1)/(−0.136 + 1) – 1 = −2.4%.

[d] Robust standard errors and p values were used.

Table B - 6 Change in HHI per M&A Deal, by Therapeutic Area, 2018–202

Therapeutic Area ^[a]^ | Pre-M&A HHI | | Post-M&A HHI | | Difference | | Percent Difference ^[b]^ | | Sample Size
Therapeutic Area ^[a]^ | Mean (SD) | Median (IQR) | Mean (SD) | Median (IQR) | Mean (SD | Median (IQR) | Mean (SD) | Median (IQR) | Sample Size
Genitourinary | 2,964 (1,089) | 3,344 (1,998) | 3,513 (701) | 3,906 (852) | 549 (505) | 562 (627) | 27.6% (30.7%) | 16.8% (42.2%) | 8
Gastrointestinal | 1,004 (158) | 1,069 (275) | 1,171 (269) | 1,173 (298) | 167 (153) | 94 (65) | 15.9% (12.3%) | 11.5% (6.4%) | 14
Hematology | 1,334 (278) | 1,345 (538) | 1,502 (253) | 1,533 (431) | 167 (59) | 171 (41) | 13.5% (6.2%) | 13.5% (4.6%) | 18
Endocrine | 1,224 (149) | 1,261 (259) | 1,378 (216) | 1,382 (344) | 154 (74) | 120 (87) | 12.2% (4.4%) | 10.4% (4.9%) | 17
Cardiovascular | 619 (77) | 621 (105) | 694 (159) | 675 (240) | 75 (107) | 86 (111) | 11.4% (16.6%) | 15.1% (18.5%) | 18
Anti-infective | 3,345 (232) | 3,460 (265) | 3,466 (102) | 3,510 (122) | 121 (187) | 65 (253) | 4.0% (6.2%) | 1.8% (8.3%) | 15
Pain Medications | 439 (54) | 435 (58) | 449 (73) | 429 (133) | 9 (86) | 17 (124) | 3.2% (18.2%) | 3.7% (29.3%) | 19
Immunomodulators | 1,671 (39) | 1,664 (35) | 1,707 (79) | 1,710 (129) | 36 (64) | 45 (81) | 2.1% (3.8%) | 2.7% (4.6%) | 12
Other ^[c]^ | 517 (47) | 527 (33) | 522 (37) | 540 (53) | 5 (62) | 27 (59) | 1.9% (12.3%) | 5.2% (11.1%) | 8
Central Nervous System | 471 (19) | 479 (13) | 475 (8) | 474 (11) | 4 (21) | −3 (30) | 1.0% (4.7%) | −0.6% (6.3%) | 19
Respiratory | 1,402 (53) | 1,387 (16) | 1,411 (50) | 1,419 (73) | 10 (80) | 39 (58) | 0.8% (5.5%) | 2.9% (4.2%) | 7
Dermatology | 628 (50) | 631 (73) | 630 (35) | 626 (28) | 2 (52) | 29 (82) | 0.7% (8.1%) | 4.4% (13.6%) | 7
Oncology | 761 (117) | 731 (246) | 719 (79) | 687 (127) | −43 (64) | −50 (110) | −4.7% (8.1%) | −5.5% (13.8%) | 19
Ophthalmology | 2,108 (101) | 2,131 (188) | 1,951 (125) | 1,958 (82) | −157 (149) | −218 (206) | −7.3% (7.1%) | −10.0% (9.1%) | 8
All Therapeutic Areas | 1,225 (900) | 928 (1,035) | 1,298 (951) | 1,041 (1,123) | 73 (189) | 48 (138) | 5.9% (14.1%) | 5.9% (13.6%) | 190

SD = standard deviation; IQR = interquartile range.

[a] Vaccines are excluded because sales data are missing at a higher rate than other therapeutic areas. M&As between 2019–2022 were analyzed to ensure one full year of data when calculating HHI before and after the M&A.

[b] Mean and median percent difference are calculated as the mean and median, respectively, of the percent difference in HHI from the year before the M&A to the year after the M&A, across all observed M&As in the therapeutic area.

[c] “Other” includes dietetics, vitamins and minerals, allergen tests, hospital solutions, and other miscellaneous categories classified by IQVIA as “other therapeutic class.”

Table B - 7 Odds Ratio of Shortage within 2 Years of M&A Date, 2018–2023

Group | Number of Drugs in Shortage within Two Years of M&A Date | | Number of Drugs [underlined: Not] in Shortage within Two Years of M&A Date | | Common Odds Ratio ^[a]^
Group | Involved in M&A | Not Involved in M&A | Involved in M&A | Not Involved in M&A | Point Estimate | 95% Lower Confidence Limit | 95% Upper Confidence Limit | p value ^[b]^
All Drugs | 112 | 1,768 | 2,017 | 25,207 | 1.2435 | 1.0316 | 1.4988 | 0.0249
Generic Drugs | 103 | 1,556 | 1,594 | 21,379 | 1.2639 | 1.0410 | 1.5345 | 0.0202
Brand Drugs | 9 | 212 | 423 | 3,828 | 1.0247 | 0.5116 | 2.0523 | 0.9453
Target’s Drugs | 45 | 1,415 | 780 | 22,644 | 2.2654 | 1.6467 | 3.1167 | <0.0001
Acquirer’s Drugs | 67 | 1,580 | 1,239 | 23,529 | 0.9918 | 0.7885 | 1.2475 | 0.9906
Essential Medicines | 25 | 375 | 318 | 3,362 | 1.1361 | 0.7916 | 1.6304 | 0.5528
Low Market Concentration | 83 | 1,260 | 1,282 | 15,338 | 1.3682 | 1.1010 | 1.7002 | 0.0055
Medium Market Concentration | 27 | 307 | 498 | 6,013 | 1.2510 | 0.8409 | 1.8611 | 0.3067
High Market Concentration | 2 | 120 | 231 | 2,899 | 0.2479 | 0.0621 | 0.9893 | 0.0465
M&As over $1 Billion in Value | 11 | 3 | 257 | 398 | 4.9769 | 1.3878 | 17.8486 | 0.0198
M&As under $1 Billion in Value | 20 | 7 | 321 | 477 | 3.6092 | 0.5976 | 21.7984 | 0.3919
Generic Drugs, Anti-infective | 2 | 113 | 141 | 2,060 | 0.2904 | 0.0723 | 1.1666 | 0.0922
Generic Drugs, Cardiovascular | 12 | 201 | 225 | 3,418 | 1.7170 | 0.9306 | 3.1680 | 0.1269
Brand Drugs, Central Nervous System | 6 | 28 | 104 | 551 | 2.8488 | 1.1246 | 7.2168 | 0.0527
Generic Drugs, Central Nervous System | 42 | 633 | 313 | 5,356 | 1.8723 | 1.3338 | 2.6282 | 0.0003
Generic Drugs, Endocrine | 13 | 28 | 109 | 1,534 | 4.0471 | 2.0184 | 8.1151 | <0.0001
Generic Drugs, Gastrointestinal | 13 | 116 | 96 | 935 | 1.6253 | 0.8571 | 3.0821 | 0.1871
Generic Drugs, Oncology | 8 | 71 | 90 | 738 | 1.1729 | 0.6064 | 2.2686 | 0.7587
Generic Drugs, Pain Medications | 13 | 145 | 228 | 1,896 | 1.1719 | 0.7323 | 1.8753 | 0.5971
Generic Drugs, Injection | 34 | 365 | 413 | 3,090 | 1.2182 | 0.8983 | 1.6521 | 0.2341
Brand Drugs, Oral Solid | 7 | 102 | 280 | 2,334 | 1.9022 | 0.8642 | 4.1870 | 0.1764
Generic Drugs, Oral Solid | 69 | 1,140 | 992 | 16,734 | 1.3499 | 1.0493 | 1.7366 | 0.0229

[a] Common odds ratios are calculated by stratifying on groups used to match M&A drugs to non-M&A drugs, i.e., calendar month and year, brand status (brand vs. generic), molecule type (biologic vs. small molecule), dosage form, and subgroup price quintile; computed as odds of going into shortage given that drug was involved in M&A divided by odds of going into shortage given that drug was not involved in M&A.

[b] p value is for the stratified Cochran-Mantel-Haenszel test of equal odds of a drug going into shortage given that it was involved in an M&A vs. not involved in an M&A.

Table B - 8 Counts of M&As by Target and Acquirer NAICS, 2010–2023 ^[a]^

Target Company NAICS | Acquiring Company NAICS ^[b]^
Target Company NAICS | 325411 Medicinal and Botanical Manufacturing | 325412 Pharmaceutical Manufacturing | 325414 Biological Product Manufacturing ^[c]^ | 541714 Research and Development in Biotechnology ^[d]^ | Total
325411: Medicinal and Botanical Manufacturing | 48 | 235 | 51 | 22 | 255
325412: Pharmaceutical Manufacturing | 186 | 2,176 | 325 | 121 | 2,289
325414: Biological Product Manufacturing ^[c]^ | 18 | 243 | 136 | 24 | 318
541714: Research and Development in Biotechnology ^[d]^ | 29 | 414 | 160 | 97 | 504
Total | 240 | 2,747 | 572 | 237 | 3,006

[a] Counts are based on primary or secondary NAICS. The sum of the counts is more than the total number of M&As (3,006) because some companies have multiple in-scope NAICS codes.

[b] Acquirers were selected for the sample if they had either NAICS 325412 or 325414. Nonetheless, the selected acquirers also work in NAICS 325411 and 541714.

[c] Excludes diagnostic manufacturer.

[d] Excludes nanobiotechnology.