# APPENDIX A DETAILED METHODOLOGY

This Appendix provides a more detailed description of the data sources, how they were merged, and the analytic methodology.

## A.1 Data Sources

### A.1.1 IQVIA National Sales Perspective (2018–2023)

IQVIA NSP is a nationally representative database covering over 90 percent of U.S. drug supply volume in terms of dollar sales, sales of packages, and API unit sales. Data are reported for multiple distribution channels, including retail, mail, and non-retail, and metrics are reported on a monthly basis, covering all payers. We used IQVIA NSP data to estimate NSP prices and the quantities sold for drugs in our sample.

We collapsed the IQVIA NSP sales data across distribution channels and pack information (including the last two digits of the 11-digit NDC), such that each row corresponded to a unique 9-digit NDC and month-year. For each 9-digit NDC, we calculated total sales in IQVIA NSP sales dollars, total sales in WAC dollars, total packages sold, total extended units sold, and total quantity sold in kg or IU. After aggregating values for each 9-digit NDC, we computed the average NSP price per extended unit as total NSP dollar sales divided by total extended units sold, and we computed the average WAC per extended unit as total WAC dollar sales divided by total extended units sold. We also collapsed the Form (TLC3) variable by selecting the first letter of each 3-digit code. We further aggregated dosage forms A (systemic oral solid regular) and B (systemic oral solid long acting) to create a single designation for oral solids and likewise combined codes F (systemic injectable regular) and G (systemic injectable long lasting) into a single designation for injections. We inflated all sales values to 2023 dollars using the seasonally adjusted consumer price index for medical care (U.S. Bureau of Labor Statistics, 2024).

Table A - 1 presents the variables included from IQVIA NSP along with those that we created for analysis purposes.

Table A - 1 IQVIA NSP Variables, January 2018 – December 2023

Variable | Description
Raw Metrics
Date | Calendar month and year
Product | Trademark name (for brand drugs and branded generics) or main active ingredient (for generics)
Brand/generic | Identifies the drug as a brand, generic, or branded generic
Product launch date | Date the product entered the U.S. market
Form TLC3 | Dosage form of the drug (tablets uncoated regular ordinary, vial regular intramuscular only, dermatological lotion, etc.)
Strength | Amount of active ingredient per pill, per unit volume, etc.
11-digit NDC | Unique three-segment number issued by FDA that identifies a drug’s labeler, product, and package
Biologic | Indicator for whether the drug is a biologic or a small molecule
Pack size | Number of containers in one package
Pack quantity | Number of individual units in one container
Molecule(s) | The molecule name of the active ingredient
Major class | Type of drug (antibacterial, antithrombotic, anti-Alzheimer, etc.)
Minor class | Sub-type of drug
Packages sold | Number of packages sold
Extended units sold | Number of pills/capsules/etc. or mL of total substance sold
API units sold ^[a]^ | Amount of API sold in grams or international units (IU)
Computed Metrics
Simplified dosage form | Simplified dosage form variable that collapses the 216 levels of Form (TLC3) into 17 broader categories
Total sales in NSP invoice dollars | Sum of NSP invoice sales across all channels and packages of that 9-digit NDC and month; represents the invoice amount charged by wholesalers or drug manufacturers
Total sales in WAC dollars | Product of the WAC and the number of packages sold, summed across all channels and packages of that 9-digit NDC and month
Average NSP price per extended unit | Total sales in NSP dollars divided by total number of extended units sold
Average WAC per extended unit | Total sales in WAC dollars divided by total number of extended units sold

[a] For substances with multiple APIs, we summed the API units of each ingredient.

### A.1.2 Drug Shortages List (2018–2023)

FDA requires drug manufacturers to provide notification to FDA about finished drug product and API manufacturing discontinuations and interruptions (U.S. Food & Drug Administration, 2024). If FDA determines that the drug is in shortage in the United States, then FDA adds the manufacturer’s drug (potentially including multiple 11-digit NDCs) to its official drug shortage list. Both CBER and the Center for Drug Evaluation and Research (CDER) maintain and publish a separate list of ongoing and recently resolved drug shortages. Drugs are only listed on the shortage list database while the shortage is ongoing and for six months after the shortage is resolved.^32^ Because many shortages that occurred between 2018–2023 could be missing from the current list, we used the Internet Archive (Internet Archive, 2024) to extract historical versions of both the CDER and CBER lists of drug shortage data.

To assemble the full historical drug shortages list from 2018–2023, we aggregated drug shortage information from three FDA data sources:

■ We downloaded all 39 available snapshots of the csv downloadable file with ongoing or recently resolved CDER drug shortages, with snapshots covering the period December 29, 2019, through December 21, 2023 (U.S. Food & Drug Administration, 2024).
■ We extracted 84 snapshots ranging from January 9, 2018, through December 1, 2022, of a shortage webpage that lists all CDER drugs in shortage (U.S. Food & Drug Administration, 2024). The extracted CDER drug shortage webpage contains a complete list of drugs in shortage but does not include the NDCs or shortage start date. For this information, a separate more detailed page was extracted for each drug on the list. We extracted 13,040 of these drug-specific pages that were linked from the 84 snapshots.
■ We extracted all 43 available snapshots of a CBER webpage with details on all ongoing drug shortages (U.S. Food & Drug Administration, 2024). The snapshots ranged from May 3, 2019, through December 22, 2023.

Combining the three sources above, we created a historical FDA drug shortage list covering the period from January 2018 through the end of December 2023 that included all 11-digit NDCs that went into shortage and the month and year the shortage began (Table A - 2). In some cases, NDCs were expressed as a 10-digit code, which represents the format reported by the manufacturer to FDA. We converted these to 11-digit codes by adding a leading 0 in the appropriate location (Anderson, 2023). In 3.9 percent of cases (137 out of 3,538 total extracted 11-digit NDCs), the NDC was missing or incomplete, and we searched the NDC Directory and did Internet research to identify the correct 11-digit NDC code. After extracting all 11-digit NDCs, we collapsed to the level of 9-digit NDC and de-duplicated records by only retaining unique combinations of 9-digit NDC and drug shortage start date.

Table A - 2 FDA Drug Shortage Variables, January 2018 – December 2023

Variable | Description
Date | Calendar month and year
9-Digit NDC | Unique two-segment number issued by FDA that identifies a drug’s labeler and product
Shortage indicator | Indicates a shortage began for the listed NDC in the listed month
Reason for shortage | When available, the cause of the drug shortage, as reported by the manufacturer
FDA center | The agency (either CDER or CBER) with jurisdiction over the drug and that reported the shortage

### A.1.3 FDA Orange Book, FDA Purple Book, and CBER’s NDA and ANDA List (2018–2023)

The Orange Book is an FDA publication of drug products that are approved on the basis of safety and effectiveness by FDA under the Federal Food, Drug, and Cosmetic Act. It lists the application number and application holder. Cumulative supplements are published monthly that show new drug approvals and changes in ownership. We used the Orange Book to establish drug ownership at the time of the M&A for most NDAs and ANDAs.

The Purple Book is an FDA dataset of FDA-licensed biological products regulated by CDER, including licensed biosimilar and interchangeable products, and FDA-licensed allergenic, cellular and gene therapy, hematologic, and vaccine products regulated by CBER. For the period from February 2020 through December 2023, we downloaded Excel files available from FDA (U.S. Food & Drug Administration, 2024). For earlier periods when these files were not published, we used all available Internet Archive extracts of lists of approved Biologics License Applications (BLAs) that were separately published by CDER (U.S. Food & Drug Administration, 2019) and CBER (U.S. Food & Drug Administration, 2019). As with the Orange Book, we used the Purple Book to establish drug ownership at the time of the M&A for BLAs.

While CBER primarily operates in the area of biological products, it also has jurisdiction over a small number of drugs approved as NDAs and ANDAs. We used the Internet Archive to extract historical snapshots of a PDF document that lists approved CBER NDA/ANDAs (U.S. Food & Drug Administration, 2024). We extracted all 14 snapshots of the PDF document that were available during the study period. In the four cases where an application changed ownership, we conducted research on the companies to determine the date of the transaction. We used these lists to supplement the drug ownership information from the Orange and Purple Books.

Using the annual publications and monthly cumulative supplements of the Orange Book (Hyman, Phelps & McNamara PC, 2024), we extracted the variables listed in Table A - 3 for all NDA and ANDA drugs listed in the Orange Book from 2018–2023. The same information was extracted for BLAs using the downloadable Excel files of the Purple Book (U.S. Food & Drug Administration, 2024), which cover the period from February 2020 through December 2023. We combined the Purple Book files with information extracted from the CDER BLA list (U.S. Food & Drug Administration, 2019) and CBER BLA list (U.S. Food & Drug Administration, 2019), which provided BLA ownership information for 2018–2019. For the few cases of NDAs and ANDAs under CBER’s jurisdiction, we gathered the information in Table A - 3 from historical archives of CBER’s NDA/ANDA listing (U.S. Food & Drug Administration, 2024).

Table A - 3 FDA Drug Ownership Variables, January 2018 – December 2023

Variable | Description
Date | Calendar month and year
Application number | Unique NDA or ANDA number issued by FDA and associated with the drug’s application for approval
Applicant | Name of company that owns listed Application at the listed month
FDA center | Indicates whether the drug is under the jurisdiction of CDER or CBER

### A.1.4 National Drug Code (NDC) Directory (2018–2023)

The NDC Directory is an FDA dataset with information on over-the-counter (OTC) and prescription drugs. It identifies drugs by their unique NDC code as well as their application number (i.e., NDA, ANDA, or BLA number). The information is collected from mandatory biannual submissions by registered drug companies. It is updated daily and represents a comprehensive listing of finished drug products that are marketed in the United States. We used the NDC Directory to associate a company’s historical ownership of a given drug application (i.e., NDA, ANDA, or BLA number) with a specific set of 9-digit NDCs that were on the market during that time.

Because discontinued drugs are removed from the NDC Directory, we extracted all 13 available snapshots of the NDC Directory (at the level of 9-digit NDCs) using the Internet Archives, which had archival dates ranging from May 2, 2017, through February 5, 2024. For months in the study period that did not have an Internet Archive snapshot, we used data from the most recent preceding snapshot. In cases where a product was approved between two snapshot dates (or was missing from all earlier snapshot(s) despite still being on the market during that period), we used data from the most recent future NDC Directory snapshot. If a single 9-digit NDC was associated with multiple application numbers at a single point in time, we retained only the earlier application number. In a very small number of cases (n=26 products, or 0.01 percent of all 9-digit NDCs), a drug was listed both as an OTC and as a prescription drug in different records; we classified these drugs as prescription drugs. For our NDC Directory dataset, we filtered out any months outside the study period (i.e., before 2018 or after 2023) (see Table A - 4).

Table A - 4 NDC Directory Variables, January 2018 – December 2023

Variable | Description
Date | Calendar month and year
Application number | Unique NDA, ANDA, or BLA number issued by FDA and associated with the drug’s application for approval; the number starts with “ANDA,” “NDA,” or “BLA,” followed by the six-digit code
9-digit NDC | Unique two-segment number issued by FDA that identifies a drug’s labeler and product
Molecule | Molecules name of the API(s); referred to as “non-proprietary name” in the NDC Directory
Product | Trade name of the drug, if a brand; referred to as the “proprietary name” in the NDC Directory
Molecule type | Either biologic or small molecule
Dosage form | The physical form (e.g., pill, solution, ointment) in which the finished drug is marketed for use
Route of administration | The manner of administering the drug to the human body (e.g., oral, intravenous, subcutaneous injection)
OTC indicator | Indicates whether or not the drug is listed exclusively as an OTC drug

### A.1.5 Essential Medicines Lists

We combined the EO EML published by FDA (U.S. Food & Drug Administration, 2020) with the ARMI EML (HHS ASPR and ARMI, 2022) and created a variable indicating which source designated each drug as essential. The EO EML includes drugs that are “most needed for patients in U.S. acute care medical facilities, which specialize in short-term treatment for severe injuries or illnesses, and urgent medical conditions” (U.S. Food & Drug Administration, 2020). Drugs in the ARMI EML “were identified as either critical for minimum patient care in acute settings or important for acute care, with no comparable alternative available” (HHS ASPR and ARMI, 2022). We used the EO EML and ARMI EML to identify essential medicines involved in M&As.

The combined EML is the only dataset (Table A - 5) that does not depend on calendar time. Since their initial publications, the lists of essential medicines have not changed. Drugs designated as essential were therefore assigned that status for their entire study period (2018–2023). Some products, like source plasma, were excluded from our study because they do not have sales information in IQVIA NSP and are not assigned an NDC number. We also excluded OTCs from the study, which include essential medicines like alcohol-based hand sanitizers. In one case, the EO EML identified “sodium bicarbonate 5% injection” as essential, while the ARMI EML did not specify a strength. We therefore designated sodium bicarbonate as essential according to both lists if the strength was 5 percent and essential according to ARMI EML if the strength was not 5 percent.

Table A - 5 Essential Medicines List Variables

Variable | Description
Date | Calendar month and year
Molecule | Molecule name of the API(s)
Dosage form | The physical form in which the finished drug is marketed for use; in some cases, this variable includes a route of administration
Strength | Quantity of the active ingredient per pill, unit volume, etc.; in most cases, this is not specified and all strengths were considered essential
EML source | Indicates whether drug is designated as essential on the EO list, ARMI list, or both

### A.1.6 FactSet (2010–2023)

FactSet is a comprehensive database on mergers and acquisitions involving public and private companies worldwide. It combines more than 200 databases from industry-leading suppliers and analytical tools into a single information system. It has data on transactions beginning in 1980 and covers over 86,000 companies. Information is sourced from “8-Ks, Business Wire, PRNewswire, Stock Exchanges, company websites, and other news sources” (FactSet, 2024). We used FactSet as the primary dataset for identifying in-scope M&A deals completed between January 1, 2010, and December 31, 2023. We indexed all transaction values to 2023 dollars using the seasonally adjusted consumer price index for medical care (U.S. Bureau of Labor Statistics, 2024).

If a transaction had a clearly erroneous value (e.g., $0 or trillions of dollars), we replaced the value using published information about the transaction. If the transaction value was not published elsewhere, we deleted the value so that it was missing but retained the transaction in our dataset. In cases where an M&A had multiple parent entities listed, we assigned the single most appropriate parent entity (e.g., based on ownership) or selected the parent company with complete financial information. We used the deal information to assign a single deal type to each M&A. Deals tagged by FactSet as a divestment, asset purchase, or forced regulatory divestiture were classified as asset transfers/divestitures. We classified deals as acquisitions if they were tagged by FactSet as being an exit, tender offer, venture backed acquirer, auction, reverse takeover, leveraged buyout, financial buyer, insolvency, going private, management buyout, privatization, secondary buyout, competing bid, unsolicited bid, investor buyout, collar, club deal private equity group, bidder controlling shareholder, and employee buyout. Deals tagged by FactSet as a merger of equals were designated as mergers. Table A - 6 presents the FactSet variables used in this analysis.

Table A - 6 FactSet Variables, January 2010 – December 2023

Variable | Description
Raw Metrics
Date | Calendar month and year when the transaction was completed
Company | Name of company involved in transaction
Role | Either acquirer or target
CUSIP number | 9-digit unique company identifier issued by American Banking Association
Primary NAICS | Classifies businesses by type of economic activity and industry; the primary NAICS indicates the main economic activity and industry of the company
Secondary NAICS | Classifies businesses based on secondary economic activities or industries they engage in
Target shares owned at transaction announcement | The percentage of the target company’s stock owned by the acquirer at the time the transaction was publicly announced
Target shares owned at completion | The percentage of the target company’s stock owned by the acquirer at the completion of the transaction
Transaction value | Calculated as base equity value plus the value of the target’s outstanding net debt (where applicable), with outstanding net debt defined as total short- and long-term interest-bearing debt less any cash and cash equivalents. The target’s outstanding net debt is only included in the Transaction Value calculation if (a) the acquirer is seeking to own 100% of the target, (b) the target is a non-financial company, and (c) the target’s outstanding net debt is publicly disclosed (or the acquirer publicly states it is assuming a specific amount of liabilities). Otherwise, transaction value is equal to amount paid for the portion of the target acquired (base equity value).
Computed Metrics
Type of transaction | Identifies the transaction as a merger, an acquisition, or a divestiture/asset transfer

Note: Definitions adapted from FactSet data dictionary (FactSet, 2024).

### A.1.7 Compustat (2010–2023)

Compustat is a database with financial and market information on public and private companies worldwide. Compustat North America has information about North American companies dating back to 1950. Compustat Global Vintage covers international companies, with data dating back to 1993. The North American dataset gathers information from annual and quarterly balance sheets, income statements, cash flow statements, and supplementary data (Standard & Poor’s, 2003). We used both Compustat North America and Compustat Global Vantage to access annual and quarterly financial information for companies involved in transactions. Compustat financial variables are reported in local currencies, which we converted into U.S. dollars (USD) using exchange rates for the month when the data were reported (International Monteary Fund, 2024). The resulting values in USD were then adjusted for inflation to 2023 USD using the seasonally adjusted consumer price index for medical care (U.S. Bureau of Labor Statistics, 2024). Table A - 7 presents the Compustat variables we used in the analysis.

Table A - 7 Compustat Variables, January 2010 – December 2023

Variable | Description
Raw Metrics
Date | Calendar month and year; for variables updated quarterly or annually, we applied the reported amounts to each corresponding month
Company | Name of company ^[a]^
Book Value of Equity | Represents the historical value of a company’s common equity. Equal to Stockholders Equity Parent, if populated. Otherwise calculated as Common Ordinary Equity plus Total Preferred/Preference Stock (Capital). Otherwise calculated as Total Assets minus Total Liabilities minus Minority Interest (balance sheet). Otherwise calculated as Total Assets minus Long-Term Liabilities.
Market Value of Equity | Represents the market value of a company’s common equity. It calculated as Price Close times Common Shares Outstanding.
Revenue | Value of the money generated from normal business operations
Computed Metrics
Book to Market Ratio | Calculated as the Book Value of Equity divided by the Market Value of Equity
Earnings before interest, taxes, depreciation and amortization (EBITDA) | Earnings before interest, taxes, depreciation, and amortization

[a] While subsidiary companies may be listed in Compustat, the reported financials are typically consolidatedwith the parent company’s financial statements (1) when the parent company owns at least 50 percent of the subsidiary, and possibly also (2) when the parent company owns 20 to 49 percent (U.S. Securities and Exchange Commission, 2020).

[b] Descriptions adapted from Compustat data dictionary and published definitions (Standard & Poor’s, 2003) (Standard & Poor’s, 2002) (Center for Research in Security Prices, 2023).

### A.1.8 DealForma (2010–2023)

DealForma is a database covering a range of pharmaceutical deals and includes information on over 35,000 companies and 4,000 M&As (DealForma, 2024). We used the DealForma data to supplement the information in FactSet. For example, DealForma identifies the type of assets involved in the M&A, the type of M&A deal, the therapeutic area and primary technology of the target company’s leading asset, the type of pharmaceutical companies involved in the M&A, the stage of development of the target products, and the type of target products (biologics, small molecules, formulations, etc.). We only used DealForma records that successfully matched to an in-scope FactSet M&A; the DealForma dataset was not used to expand the sample of M&A deals. We did, however, use DealForma to implement some exclusion criteria, specifically the exclusion of cell/gene therapy companies, and the exclusion of deals involving devices or diagnostics.

We also used DealForma to assist in classifying deals. Deals marked as acquisitions or acquisition options in DealForma were designated as acquisitions in our dataset. Deals categorized as reverse mergers in DealForma were designated as mergers. Deals marked as a business unit purchase or platform/product purchase in DealForma were designated as asset transfers/divestitures in our dataset. To harmonize deal types between FactSet and DealForma, we deferred to the DealForma classification type if available, and used the FactSet classification otherwise.

Table A - 8 DealForma Variables, 2010 – 2023

Variable | Description
Target | Target company in transaction
Acquirer | Acquirer company in transaction
Stage signed | Stage of acquired company’s most advanced asset in deal
Deal type | Type of deal (acquisition, company formation, platform/product purchase, etc.)
Primary therapeutic area | Primary therapy area of the deal based on most advanced asset of target company
Primary technology | Target company’s primary modality/technology of its leading asset
Asset type | Category of target company’s leading asset in deal (drug, device, company/business/facility, etc.)
Deal status | Indicates if the M&A or asset purchase is still active, was terminated, or was completed

## A.2 Merging All Datasets

We used the historical NDC Directory as the basis for combining all datasets because the NDC Directory contains the most comprehensive accounting of finished human prescription drugs (U.S. Food & Drug Administration, 2022), with records for each month from January 2018 through December 2023. The final dataset thus contained a single observation for each unique 9-digit NDC, month, and year. Figure A - 1 shows each step of merging and the number of matching drugs (i.e., 9-digit NDCs) at each stage with non-missing data from all merged datasets.

Figure A - 1 Number of Drugs (9-digit NDCs) by Merging Step

This figure shows the number of drugs (i.e., 9-digit NDCs) at each stage of data merging. The compiled historical NDC Directories had 103,683 drugs. After merging with IQVIA NSP, there were 34,226 drugs. Next, after merging with the FDA Applicant data sources (i.e., Orange Book, Purple Book, and CBER NDA/ANDA Lists), there were 31,837 drugs. From this point, the number of drugs did not decrease as additional datasets were merged, including Compustat, FactSet, DealForma, the FDA Drug Shortage List, and the Essential Medicines Lists.

To construct the analytic dataset, we began with the historical NDC Directory (see step 1 of Figure A - 1). Using month and 9-digit NDC, we merged the processed IQVIA NSP dataset into the historical NDC Directory (step 2), which led to a match for 34,226 drugs (i.e., 9-digit NDCs). Next, using month and application number, we merged the historical FDA applicant information (consisting of the Orange Book records, Purple Book records, and CBER NDA/ANDA records) into the analytic dataset (step 3), which resulted in only a slight reduction in the number of records. We next merged in the Compustat data by matching the Compustat company name to the FDA Applicant name (step 4). This step involved harmonizing the Applicant names as they appear across all historical records of the Orange Book, Purple Book, and CBER NDA/ANDA list, and then matching the harmonized names to the company names in Compustat. We did this using a manual review, which was aided by a fuzzy match to generate an initial list of similar names that were candidates for grouping into a single harmonized name. The expectation was that many records would not match to the Compustat data, since Compustat primarily contains data on public companies required to disclose their financial information.

Next, we merged FactSet/DealForma data into the analytic dataset using CUSIP number (step 5), which is also present in Compustat. Before this merging, we combined the FactSet and DealForma datasets by matching the names of the acquiring companies and the target companies, as well as an approximate match of the date the deal was announced. As with other matching procedures, we used fuzzy matching to generate an initial list of candidate matches and then performed manual review to select the valid matches. To harmonize the classification of deal type, we relied on the DealForma designation if it was available, and we used the FactSet designation otherwise.

We also merged in the drug shortages records using month and 9-digit NDC (step 6), and the EML information using the molecule, dosage form, and strength, all of which also appear in the NDC Directory (step 7). In step 6, we successfully matched 89.2 percent of the extracted 9-digit NDCs in the drug shortage lists to our analytic dataset. The remaining 10.8 percent likely include drugs that are out of scope (e.g., OTCs, products that do not have NDCs, products that do not have sales data in IQVIA NSP). In step 7, to merge the EML data, we performed broad word searches of the drugs described in the EML, and then manually reviewed matches with the NDC Directory to identify drugs that meet the EML description of active ingredients, route of administration, strength in some cases. Where the EML specifies active ingredient(s), we designated drugs in the NDC Directory as essential only if all of the drug’s active ingredients were listed in the EML. Drugs with additional active ingredients not specified by the EML were not designated as essential since both the FDA EO EML and the ASPR EML include additional line items to indicate additional active ingredients as essential where relevant (e.g., the FDA EO EML and the ASPR EML both include ceftazidime separately from ceftazidime-avibactam). In cases where the EML specifies a type of product rather than the active ingredients (e.g., “continuous renal replacement solution,” “thrombin products,” “tetanus vaccine”), we included all products meeting this description, even if, e.g., the tetanus vaccine contains other antigens besides tetanus toxoids, such as diphtheria toxoids or pertussis antigens. The EML and NDC Directory did not always describe the route of administration to the same degree of specificity (e.g., the EML lists “intramuscular” and NDC Directory lists “injection”). We therefore created a crosswalk of exact matches and possible matches between the two data sources and then performed manual review to identify valid matches. In cases where the EML specified a particular strength, we only designated NDCs as essential if they had the specified strengths.

## A.3 Detailed Analytic Framework

### A.3.1 Descriptive Analysis of M&As

We analyzed the characteristics of pharmaceutical M&As using the full sample of M&As meeting the inclusion criteria from January 2010 through December 2023. Within this M&A sample, the rate of missingness varied widely by variable. Rather than considering only full and complete records, we analyzed each M&A variable separately, using the available non-missing records of that variable. We performed Augmented Dickey-Fuller trend tests to assess the stationarity of the observed time series and identify changes, e.g., due to trends or seasonality. To calculate the average annual percent growth in the median M&A transaction value, we fit a linear model of the form:

median MA value = α exp ( λ t ) or ln ( median M & A value ) = α + λ t Equation 1: The equation for the median M&A value is given by alpha times the exponential of lambda times t, or alternatively, the natural logarithm of the median M&A value equals alpha plus lambda times t. (1)

where the initial value α and growth rate λ are parameters to be estimated. We calculated the average annual growth from the estimated growth rate parameter, as exp(λ) – 1.

### A.3.2 Descriptive Analysis of Drugs

Using the full drug dataset of 31,837 drugs, we evaluated the characteristics of drugs involved in M&As. This drug-level dataset included data from January 2018 through December 2023, which is the period of time for which IQVIA NSP data were available and monthly historical snapshots of FDA datasets were extracted. We used this dataset to evaluate the frequency and rate at which M&As target various types of drugs in the sample (e.g., brands versus generics, therapeutic area, type of molecule), and to calculate the odds ratio of a drug being involved in an M&A if it is essential versus non-essential.

When analyzing the drugs involved in M&As, we included (a) all drugs owned by the target company and transferred to the acquiring company, (b) any brand drugs owned by the acquiring company with the same therapeutic area as the target drugs, and (c) any generic drugs owned by the acquiring company with the same dosage form as the target drugs.^33^ In cases where the target company only sold certain drugs from its portfolio (and did not transfer all of its marketed drugs), we identified the specific drugs involved in the M&A and flagged only those drugs that we could identify as having transferred ownership. For drug-level analyses, we considered each unique 9-digit NDC to be a different drug. We linked the M&A data to the IQVIA NSP data and designated a main drug portfolio type (original biologics, biosimilars, small molecule brands, or small molecule generics) to each company based on its largest line of business by sales dollars.

### A.3.3 Matched Analysis of Drug Shortages

This analysis required identifying a cohort of “control” drugs that were not involved in an M&A but had similar characteristics as the cohort of “treated” drugs that were involved in M&As. We performed exact matching to remove imbalance in possible confounders. For each drug involved in an M&A in a given month, we identified all “control” drugs that were marketed in that same month and had the same brand status (brand versus generic), molecule type (small molecule versus biologic), dosage form, and price group. The price groups were formed by calculating quintiles of the NSP price per extended unit over the full dataset within groupings of brand status, molecule type, and dosage form. We matched on price because lower-cost drugs may be more likely to go into shortage. We repeated this matching process separately for each month in the dataset when an M&A occurred. Matching on the month and year allowed us to compare the M&A drugs to the non-M&A drugs (a) over equal periods of time, which is important since the probability of drug shortage generally increases as more time passes, and (b) over the same calendar time, which reduces the impact of any temporal confounders. In a given month, non-M&A drugs were selected from the set of drugs in our sample that were not involved in an M&A at any point during the study period. A single non-M&A drug was permitted to serve as a control in more than one month if the drug’s matching group(s) were involved in multiple M&As over the study period.^34^ In this report, we use the term “matching group” to refer to the distinct groupings of month, form, brand status, molecule type, and price. To maximize sample size, we retained all data for any matching groups with at least one M&A drug and at least one non-M&A drug.

Using this matched dataset, we calculated the common (i.e., adjusted) odds ratio of going into shortage within a two-year period of the M&A date. We calculated the odds ratio for all drugs in the matched drug dataset and also for various subgroups (e.g., therapeutic classes, dosage forms). Odds ratios were calculated as the odds of going into shortage given involvement in an M&A divided by the odds of going into shortage given no involvement in an M&A. We stratified the calculation of common odds ratios using the matching groups to control for between-group differences in the baseline odds of going into shortage. We performed the Cochran-Mantel-Haenszel (CMH) test to assess whether the common odds ratio differed significantly from the null value of 1. The common odds ratio was calculated using Equation 2, summing over all matching groups. In Equation 2, n_g_ represents the number of drugs in a given matching group g (e.g., n_g_^(M&A, short)^ is the number of drugs in group g that were involved in an M&A and went into shortage within two years of the M&A date), and N_g_ is the total number of drugs in group g.

OR_common_ = (g ( n_g_^( M & A, short )^ n_g_^( non-M & A, not short )^ / N_g_ ))/(g ( n_g_^( non-M & A, short )^ n_g_^( M & A, not short )^ / N_g_ )) Equation 2: The equation for OR common is the sum over g of the product of n sub g for M&A short and n sub g for non-M&A not short, divided by N sub g, all divided by the sum over g of the product of n sub g for non-M&A short and n sub g for M&A not short, divided by N sub g. (2)

### A.3.4 Matched Analysis of Price Changes and Quantity Sold

We also used the matched dataset to compare the cohort of M&A drugs to the cohort of non-M&A drugs and assess whether they experienced different changes in price or quantity sold after the M&A date. Following the method of Bonaime & Wang (2024), we estimated the change in price and quantity sold in the following way, considering post-M&A periods of X = 1–6 months, 1–12 months, and 13–24 months, excluding the month of the M&A^35^ from both the pre-M&A and post-M&A periods.

Δ price = ln ( (price in months X after M & A)/(price in months 1-12 before M & A) ) Equation 3: The change in price, denoted as delta price, is the natural logarithm of the ratio of the price in months X after M&A to the price in months 1 to 12 before M&A. (3)

Δ quantity = ln ( (quantity sold in months X after M & A)/(quantity sold in months 1-12 before M & A) ) Equation 4: The change in quantity, denoted as delta quantity, is the natural logarithm of the ratio of the quantity sold in months X after M&A to the quantity sold in months 1 to 12 before M&A. (4)

Because we aggregated to the level of 9-digit NDC (which collapses across packages with different sizes, etc.), we estimated prices using the per-extended-unit price:

price in months X = (total sales in months X)/(total extended units sold in months X) Equation 5: The price in months X is calculated as the total sales in months X divided by the total extended units sold in months X. (5)

We used a linear model with robust standard errors to test the statistical significance of the difference between the natural log of the price ratio, ∆price, for M&A drugs versus non-M&A drugs. We performed the same procedure for the natural log of the quantity ratio, ∆quantity. Letting x_involved in M&A_ be an indicator for whether the drug was involved in an M&A and x_g_ represent the matching group^36^, the model was specified as follows:

Δ price or Δ quantity = β_0_ + β_1_ x_involved in M & A_ + β_2_ x_g_ Equation 6: The change in price or quantity, denoted as delta price or delta quantity, is equal to beta zero plus beta one times x involved in M&A plus beta two times x sub g. (6)

Separate regression models were fitted for brand drugs and generic drugs. p values for the coefficients β_1_ were used to assess the strength of the association. The average effect of M&As on the pre-to-post percent change is exp(β_1_)−1, which corresponds to the percent change for M&A drugs compared to non-M&A drugs. We also calculated the average expected pre-to-post percent change in price across all n observations in the sample, which we then transformed out of the logarithmic scale:

( (price in months X after M & A)/(price in 12 months before M & A) )_non-MA, mean_ = exp ( (1)/(n) ∑ ( β_0_ + β_2_ x_g_ ) ) Equation 7: The mean ratio of the price in months X after M&A to the price in 12 months before M&A for non-M&A is equal to the exponential of 1 over n times the sum of beta zero plus beta two times x sub g. (7)

( (price in months X after M & A)/(price in 12 months before M & A) )_MA, mean_ = exp ( (1)/(n) ∑ ( β_0_ + β_1_ + β_2_ x_g_ ) ) Equation 8: The mean ratio of the price in months X after M&A to the price in 12 months before M&A for M&A is equal to the exponential of 1 over n times the sum of beta zero plus beta one plus beta two times x sub g. (8)

We considered three price metrics. The WAC is the “list price” offered by the drug manufacturer. It is rarely actually paid but often serves as a basis for price negotiations with payers or plan sponsors. We also analyzed the IQVIA NSP invoice price paid to the manufacturer or wholesaler by healthcare providers (pharmacies, outpatient facilities, hospitals, etc.). While a helpful benchmark, the NSP invoice price does not account for off-invoice discounts or rebates.

### A.3.5 Market Concentration and HHI

We defined drug markets by therapeutic area and calculated the HHI within each market over a one-year period before and after each M&A in that therapeutic area. For these calculations, we harmonized company names across and within the various FDA drug ownership data sources to account for variations in spelling, abbreviations, etc. We used these harmonized FDA company identifiers to calculate each company’s market share. Our harmonized company identifiers, however, did not collapse subsidiaries into their parent companies. When calculating HHI before or after the M&A, both the pre-M&A and post-M&A periods excluded the month when the M&A occurred. We mapped the IQVIA NSP “Major Class” variable onto 14 main therapeutic areas: Genitourinary, Gastrointestinal, Endocrine, Hematology, Cardiovascular, Anti-infective, Pain Medication, Immunomodulators, Central Nervous System, Respiratory, Dermatology, Oncology, Ophthalmology, Vaccines, and Other (which includes dietetics, vitamins and minerals, allergen tests, hospital solutions, and other miscellaneous categories classified by IQVIA as “Other Therapeutic Class”). For this analysis, we used data from 2018–2023 but only included M&As conducted during 2019-2022 in order to guarantee that one full year of sales data was available for the pre-M&A and post-M&A HHI calculations. We computed HHI as:

HHI_m_ = ∑_i_ ( (company i ' s one-year IQVIA NSP sales in drug market m)/(sum of all IQVIA NSP sales in drug market m) × 100 )^2^ Equation 9: The Herfindahl-Hirschman Index (HHI) for market m is the sum over all companies i of the square of the ratio of company i’s one-year IQVIA NSP sales in drug market m to the sum of all IQVIA NSP sales in drug market m, multiplied by 100. (9)

For each market, we calculated the average change in HHI per M&A in that therapeutic area. We also computed the average change in HHI per M&A across all markets (still defining markets by therapeutic area). We used one-sample Wilcoxon signed rank test to assess the statistical significance of changes in HHI.

32 FDA states, “Resolved shortages remain on the list for 6 months and discontinued shortages remain on the list for 1 year.” (U.S. Food & Drug Administration, 2024)

33 We used the IQVIA NSP variable “major class” to identify matching therapeutic areas. To identify matching dosage forms, we used the IQVIA variable “Form (TCL1).” We combined oral solids into a single group and combined injections into a single group.

34 Each drug’s price group was reassigned in each month because drugs change prices over time, and to identify drugs that were similar at the time of the M&A.

35 We filtered the matched drug dataset based on the required pre-M&A and post-M&A periods. For example, we excluded M&As that occurred in 2018 because there was not sufficient data to measure the average price in the 12 months prior to the M&A.

36 The matching group x_g_ is a categorical variable with more than two levels and was coded as a series of dummy variables in the regression, i.e., β_2_ x_g_ = Σ_g = 1_^G − 1^ β_2_^( g )^ x_g_ , where x_g_ is the binary indicator variable for the g^th^ group out of G total groups and β_2_^(g)^ is the corresponding coefficient.