# ABBREVIATIONS

Abbreviations: Definitions
ANDA: Abbreviated new drug application
API: Active pharmaceutical ingredient
ARMI: Advanced Regenerative Manufacturing Institute
ASPR: Administration for Strategic Preparedness and Response
BLA: Biologics license application
CBER: Center for Biologics Evaluation and Research
CDER: Center for Drug Evaluation and Research
CMH: Cochran-Mantel-Haenszel
CUSIP: Committee on Uniform Securities Identification Procedures
DOJ: Department of Justice
EBITDA: Earnings before interest, taxes, depreciation, and amortization
EML: Essential medicines list
EO: Executive Order
FDA: U.S. Food & Drug Administration
FDF: Finished dosage form
HHI: Herfindahl-Hirschman Index
IQR: Interquartile range
M&A: Merger and acquisition
NAICS: North American Industry Classification System
NDA: New drug application
NDC: National Drug Code
NSP: National Sales Perspective
OTC: Over-the-counter
PBM: Pharmacy benefit manager
SD: Standard deviation
USD: U.S. dollars
WAC: Wholesale acquisition cost