# References

1 Bosworth A, Sheingold S, Finegold K, De Lew N, Sommers BD. Price Increases for Prescription Drugs, 2016–2022. Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services; 2022.
2 National Academies of Sciences, Engineering, and Medicine. Building Resilience into the Nation's Medical Product Supply Chains. National Academies Press (US); 2022.
3 Cutler DM. The demise of the blockbuster? N Engl J Med. 2007;356(13):1292–1293. doi:10.1056/NEJMp078020 17392299
4 Bennani YL. Drug discovery in the next decade: innovation needed ASAP. Drug Discov Today. 2011;16(17-18):779–792. doi:10.1016/j.drudis.2011.06.004 21704185
5 Sharp D. Not-for-profit drugs—no longer an oxymoron? Lancet. 2004;364(9444):1472–1474. doi:10.1016/S0140-6736(04)17291-7 15500876
6 Liljenquist D, Bai G, Anderson GF. Addressing generic-drug market failures—the case for establishing a nonprofit manufacturer. N Engl J Med. 2018;378(20):1857–1859. doi:10.1056/NEJMp1800861 29768140
7 Dredge C, Scholtes S. The health care utility model: a novel approach to doing business. NEJM Catalyst (non-issue content). 2021;2(4). doi:10.1056/CAT.21.0189
8 Jaroslawski S, Toumi M, Auquier P, Dussart C. Non-profit drug research and development at a crossroads. Pharm Res. 2018;35(3):52. doi:10.1007/s11095-018-2351-3 29417233
9 Conti RM, Meltzer DO, Ratain MJ. Nonprofit biomedical companies. Clin Pharmacol Ther. 2008;84(2):194–197. doi:10.1038/clpt.2008.123 18679181
10 Medicines360. Nonprofit Pharma, Advancing a New Model for Equitable Access to Medicines. Medicines 360; 2023. https://medicines360.org/wp-content/uploads/M360_CaseStudy_FINAL_v4_single.pdf
11 Handy F. Coexistence of nonprofit, for-profit and public sector institutions. Ann Public Coop Econ. 1997;68(2):201–223. doi:10.1111/1467-8292.00043
12 Consolidated Appropriations Act 2023, Pub L 117–328, 136 Stat 4459. https://www.congress.gov/bill/117th-congress/house-bill/2617
13 Internal Revenue Service. Exempt organization types. Accessed September 2023. https://www.irs.gov/charities-nonprofits/exempt-organization-types
14 Dalton CM, Bradford WD. Better together: coexistence of for-profit and nonprofit firms with an application to the U.S. hospice industry. J Health Econ. 2019;63:1–18. doi:10.1016/j.jhealeco.2018.10.001 30439574
15 Marwell NP, McInerney P-B. The nonprofit/for-profit continuum: theorizing the dynamics of mixed-form markets. Nonprofit Volunt Sect Q. 2005;34(1):7–28. doi:10.1177/0899764004269739
16 Rose-Ackerman S. Competition between non-profits and for-profits: entry and growth. Voluntas. 1990;1(1):13–25. doi:10.1007/BF01398489
17 Stevens AJ, Jensen JJ, Wyller K, Kilgore PC, Chatterjee S, Rohrbaugh ML. The role of public-sector research in the discovery of drugs and vaccines. N Engl J Med. 2011;364(6):535–541. doi:10.1056/NEJMsa1008268 21306239
18 Frye S, Crosby M, Edwards T, Juliano R. US academic drug discovery. Nat Rev Drug Discov. 2011;10(6):409–410. doi:10.1038/nrd3462 21629285
19 Kneller R. The importance of new companies for drug discovery: origins of a decade of new drugs. Nat Rev Drug Discov. 2010;9(11):867–882. doi:10.1038/nrd3251 21031002
20 Frank GD, Jong L, Collins N, Spack EG. Nonprofit model for drug discovery and development. Drug Dev Res. 2007;68(4):186–196. doi:10.1002/ddr.20181
21 Chakravarthy R, Cotter K, DiMasi J, Milne CP, Wendel N. Public- and private-sector contributions to the research and development of the most transformational drugs in the past 25 years: from theory to therapy. Ther Innov Regul Sci. 2016;50(6):759–768. doi:10.1177/2168479016648730 30231735
22 Moos WH, Mirsalis JC. Nonprofit organizations and pharmaceutical research and development. Drug Dev Res. 2009;70(7):461–471. doi:10.1002/ddr.20326
23 Hale VG, Woo K, Lipton HL. Oxymoron no more: the potential of nonprofit drug companies to deliver on the promise of medicines for the developing world. Health Aff. 2005;24(4):1057–1063. doi:10.1377/hlthaff.24.4.1057
24 Cystic Fibrosis Foundation. Our venture philanthropy model. Accessed September 2023. https://www.cff.org/aboutus/our-venture-philanthropy-model
25 Pollack A. Deal by Cystic Fibrosis Foundation raises cash and some concern. The New York Times. November 19, 2014. Accessed March 17, 2023. https://www.nytimes.com/2014/11/19/business/for-cystic-fibrosis-foundation-venture-yields-windfall-in-hope-and-cash.html
26 Bush A, Simmonds NJ. Hot off the breath: 'I've a cost for'—the 64 million dollar question. Thorax. 2012;67(5):382–384. doi:10.1136/thoraxjnl-2012-201798 22407889
27 Nolen S, Robbins R. The drug is a ‘miracle’ but these families can’t get it. The New York Times. February 7, 2023. Accessed March 17, 2023. https://www.nytimes.com/2023/02/07/health/cystic-fibrosis-drug-trikafta.html
28 Bansal R, De Backer R, Ranade V. What’s behind the pharmaceutical sector’s M&A push. McKinsey & Company. October 10, 2018. https://www.mckinsey.com/capabilities/strategy-and-corporate-finance/our-insights/whats-behind-the-pharmaceutical-sectors-m-and-a-push#/
29 U.S. Government Accountability Office. Drug Industry: Profits, Research and Development Spending, and Merger and Acquisition Deals. 2017. GAO-18-40. https://www.gao.gov/assets/gao-18-40.pdf
30 Weisman R. Nonprofit vows to lower generic drug costs. The Boston Globe. December 13, 2015. Accessed March 30, 2023. https://www.bostonglobe.com/business/2015/12/13/nonprofit-aims-make-affordable-generic-drugs/u0kd8MHfZmawSzAh0pRnKI/story.html
31 CIVICA. Civica is launched! Accessed September 2023. https://civicarx.org/timeline-2018/#sept-1
32 Internal Revenue Service. Exemption requirements—501(c)(3) organizations. Accessed September 2023. https://www.irs.gov/charities-non-profits/charitable-organizations/exemption-requirements-501c3-organizations
33 Internal Revenue Service. Social welfare organizations. Accessed March 2023. https://www.irs.gov/charities-nonprofits/other-non-profits/social-welfare-organizations
34 Internal Revenue Service. About Form 990, Return of Organization Exempt from Income Tax. Accessed March 2023. https://www.irs.gov/forms-pubs/about-form-990
35 Ledley FD, McCoy SS, Vaughan G, Cleary EG. Profitability of large pharmaceutical companies compared with other large public companies. JAMA. 2020;323(9):834–843. doi:10.1001/jama.2020.0442 32125401
36 CIVICA. Making quality generic and biosimilar medications available at fair prices. Accessed September 2023. https://civicarx.org/medications/
37 CIVICA. CivicaScript announces a new health plan partner, a new president, and a new drug manufacturing partner. June 5, 2021. https://civicarx.org/civicascript-the-newly-named-civica-initiative/#
38 Dredge C, Scholtes S. The health care utility model: a novel approach to doing business. NEJM Catalyst (non-issue content). 2021;2(4). doi:10.1056/CAT.21.0189
39 Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. Report on the Affordability of Insulin. December 16, 2022. https://aspe.hhs.gov/reports/insulin-affordability-rtc
40 Gaffney A, Himmelstein DU, Woolhandler S. Prevalence and correlates of patient rationing of insulin in the United States: a national survey. Ann Intern Med. 2022;175(11):1623–1626. doi:10.7326/M22-2477 36252243
41 Wingrove P, Bhanvi S. Novo Nordisk to slash US insulin prices, following move by Eli Lilly. Reuters. March 14, 2023. https://www.reuters.com/business/healthcare-pharmaceuticals/novo-nordisk-cut-price-insulin-by-up-75-wsj-2023-03-14/
42 Lovelace B. Sanofi announces insulin price cap after actions by Eli Lilly and Novo Nordisk. NBC News. March 16, 2023. https://www.nbcnews.com/health/health-news/sanofi-insulin-price-cap-rcna75346
43 Murphy T. Lilly plans to slash some insulin prices, expand cost cap. The Associated Press. March 2, 2023. https://apnews.com/article/insulin-diabetes-humalog-humulin-prescription-drugs-eli-lilly-lantus-419db92bfe554894bdc9c7463f2f3183?utm
44 Sable-Smith B, Young S. Eli Lilly slashed insulin prices. This starts a race to the bottom. Fierce Healthcare. March 3, 2023. https://www.fiercehealthcare.com/finance/eli-lilly-slashed-insulin-prices-starts-race-bottom
45 Rosenberg M, Chai G, Mehta S, Schick A. Trends and economic drivers for United States naloxone pricing, January 2006 to February 2017. Addict Behav. 2018;86:86–89. doi:10.1016/j.addbeh.2018.05.006 29914719
46 Statement from FDA Commissioner Scott Gottlieb, M.D., on unprecedented new efforts to support development of over-the-counter naloxone to help reduce opioid overdose deaths. Press release. U.S. Food and Drug Administration. January 17, 2019. https://www.fda.gov/news-events/press-announcements/statement-fda-commissioner-scott-gottlieb-md-unprecedented-new-efforts-support-development-over
47 Over-the-counter naloxone one step closer as Harm Reduction Therapeutics initiates a rolling submission of its New Drug Application (NDA) to U.S. Food and Drug Administration for RiVive™ (3.0 mg intranasal naloxone) for emergency treatment of opioid overdose. Press release. Harm Reduction Therapeutics. October 11, 2022. https://www.harmreductiontherapeutics.org/wp-content/uploads/2022/12/HRT-Rolling-Submission-PR.11Oct20226668.pdf
48 Emergent BioSolutions announces U.S. FDA acceptance and priority review of supplemental New Drug Application for over-the-counter NARCAN® (naloxone HCl) Nasal Spray. Press release. Emergent BioSolutions. December 6, 2022. https://investors.emergentbiosolutions.com/news-releases/news-release-details/emergent-biosolutions-announces-us-fda-acceptance-and-priority
49 FDA approves first over-the-counter naloxone nasal spray. Press release. U.S. Food and Drug Administration. March 29, 2023. https://www.fda.gov/news-events/press-announcements/fda-approves-first-over-counter-naloxone-nasal-spray
50 FDA approves second over-the-counter naloxone nasal spray product. Press release. U.S. Food and Drug Administration. July 28, 2023. https://www.fda.gov/news-events/press-announcements/fda-approves-second-over-counter-naloxone-nasal-spray-product#:~:text
51 Drugs.com. Targretin prices, coupons and patient assistance programs. Accessed September 2023. https://www.drugs.com/price-guide/targretin#:~:text=The%20cost%20for%20Targretin%20oral,on%20the%20pharmacy%20you%20visit
52 Bell J. Aiming for price transparency, Civica Rx hits snag with bundled payments. BIOPHARMADIVE. January 27, 2019. Accessed March 30, 2023. https://www.biopharmadive.com/news/dia-civicarx-drug-pricing-transparency-hospital-payments/557541/
53 Spicer M. US FDA expects no change in naloxone access barrier if prices high for potential OTC products. HBW Citeline. August 20, 2022. https://hbw.citeline.com/RS152876/US-FDA-Expects-No-Change-In-Naloxone-Access-Barrier-If-Prices-High-For-Potential-OTC-Products
54 U.S. Food and Drug Administration. Drug Shortages: Root Causes and Potential Solutions. Drug Shortages Task Force; 2020. https://www.fda.gov/media/131130/download?attachment
55 Dredge C, Liljenquist D, Scholtes S. Disruptive collaboration: a thesis for pro-competitive collaboration in health care. NEJM Catalyst (non-issue content). 2022;3(2). doi:10.1056/CAT.22.0057
56 Testimony to the United States Senate Committee on Finance: COVID-19 & Beyond: Oversight of the FDA’s Foreign Drug Manufacturing Inspection Process. U.S. Senate Committee on Finance. June 2, 2020. https://www.finance.senate.gov/hearings/covid-19-and-beyond-oversight-of-the-fdas-foreign-drug-manufacturing-inspection-process
57 Capps CS, Carlton DW, David G. Antitrust treatment of nonprofits: should hospitals receive special care? Econ Inq. 2020;58(3):1183–1199. doi:10.1111/ecin.12881
58 FDA publishes list of essential medicines, medical countermeasures, critical inputs required by Executive Order. Press release. U.S. Food and Drug Administration. October 30, 2020. https://www.fda.gov/news-events/press-announcements/fda-publishes-list-essential-medicines-medical-countermeasures-critical-inputs-required-executive
59 U.S. Food and Drug Administration. Executive Order 13944 list of essential medicines, medical countermeasures, and critical inputs. May 23, 2022. https://www.fda.gov/about-fda/reports/executive-order-13944-list-essential-medicines-medical-countermeasures-and-critical-inputs
60 World Health Organization. WHO Model List of Essential Medicines—22nd List. WHO; 2021. https://www.who.int/publications/i/item/WHO-MHP-HPS-EML-2021.02
61 Innovative Genomics Institute. Public impact. Accessed September 2023. https://innovativegenomics.org/programs/public-impact/
62 Piddock LJV, Paccaud J- P, O'Brien S, Childs M, Malpani R, Balasegaram M. A nonprofit drug development model is part of the antimicrobial resistance (AMR) solution. Clin Infect Dis. 2022;74(10):1866–1871. doi:10.1093/cid/ciab887 34618892
63 Nielsen TB, Brass EP, Gilbert DN, Bartlett JG, Spellberg B. Sustainable discovery and development of antibiotics—is a nonprofit approach the future? N Engl J Med. 2019;381(6):503–505. doi:10.1056/NEJMp1905589 31216396
64 Outterson K, Rex JH. Evaluating for-profit public benefit corporations as an additional structure for antibiotic development and commercialization. Transl Res. 2020;220:182–190. doi:10.1016/j.trsl.2020.02.006 32165059
65 Collins FS. Mining for therapeutic gold. Nat Rev Drug Discov. 2011;10(6):397. doi:10.1038/nrd3461 21629277
66 Cvek B. Nonprofit drugs as the salvation of the world's healthcare systems: the case of Antabuse (disulfiram). Drug Discov Today. 2012;17(9-10):409–412. doi:10.1016/j.drudis.2011.12.010 22192884
67 Roth LP, Sanders JN, Simmons RG, Bullock H, Jacobson E, Turok DK. Changes in uptake and cost of long-acting reversible contraceptive devices following the introduction of a new low-cost levonorgestrel IUD in Utah's Title X clinics: a retrospective review. Contraception. 2018;98(1):63–68. doi:10.1016/j.contraception.2018.03.029 29574095
68 Cvek B. Multiple deadlocks in the development of nonprofit drugs. Drug Discov Today. 2022;27(9):2411–2414. doi:10.1016/j.drudis.2022.06.001 35667629
69 Department of Health and Human Services, Centers for Medicare & Medicaid Services. Medicare FY2020 IPPS Final Rule, 84 FR 42044. 2019. https://www.federalregister.gov/documents/2019/08/16/2019-16762/medicare-program-hospital-inpatient-prospective-payment-systems-for-acute-care-hospitals-and-the
70 Kansteiner F. Civica Rx lays out $124M sterile injectables plant, pegged to supply COVID-19 drugs and more. Fierce Pharma. January 25, 2021. https://www.fiercepharma.com/manufacturing/civica-rx-lays-out-124-5-million-sterile-injectables-plant-pegged-to-supply-covid-19
71 Phlow Corporation awarded $354 million HHS/ASPR/BARDA contract to manufacture essential medicines in shortage. Press release. PR Newswire. May 19, 2020. https://www.prnewswire.com/news-releases/phlow-corporation-awarded-354-million-hhsasprbarda-contract-to-manufacture-essential-medicines-in-shortage-301061648.html
72 Eastern Research Group, Inc. Examination of Clinical Trial Costs and Barriers for Drug Development. Submitted to the Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services; 2014. https://aspe.hhs.gov/reports/examination-clinical-trial-costs-barriers-drug-development-0
73 U.S. Food and Drug Administration. Small business assistance. Accessed September 2023. https://www.fda.gov/industry/small-business-assistance
74 U.S. Food and Drug Administration. Prescription drug user fee amendments. Accessed September 2023. https://www.fda.gov/industry/fda-user-fee-programs/prescription-drug-user-fee-amendments
75 Eastern Research Group, Inc. Cost of Generic Drug Development and Approval. Submitted to the Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services; 2022. https://aspe.hhs.gov/reports/cost-generic-drugs
76 RTI. FDA approves treatment targeting drug-resistant tuberculosis backed by RTI scientist. TechWire. August 14, 2019. Accessed March 17, 2023. https://wraltechwire.com/2019/08/14/fda-approves-treatment-targeting-drug-resistant-tuberculosis-backed-by-rti-scientist/
77 Vieira MF, Kimmitt R, Navarro D, Bezruki A, Moon S. Advancing innovation and access to medicines: the achievements and unrealized potential of the product development partnership model. In Andonova LB, Faul MV, Piselli D, eds. Partnerships for Sustainability in Contemporary Global Governance. Routledge; 2022:120–143.
78 Curtis KM, Nguyen A, Reeves JA, Clark EA, Folger SG, Whiteman MK. Update to U.S. selected practice recommendations for contraceptive use: self-administration of subcutaneous depot medroxyprogesterone acetate. MMWR Morb Mortal Wkly Rep. 2021;70(20):739–743. doi:10.15585/mmwr.mm7020a2 34014910
79 Chin-Dusting J, Mizrahi J, Jennings G, Fitzgerald D. Finding improved medicines: the role of academic–industrial collaboration. Nat Rev Drug Discov. 2005;4(11):891–897. doi:10.1038/nrd1879 16247439