# Discussion and Conclusion

The findings from this report suggest that nonprofit pharmaceutical companies have the potential to address drug shortages and enhance access to affordable and essential medicines. However, their sustainability and effectiveness may be limited due to low production volumes, a complex tax system, ineligibility for small business funding sources, and to some extent, lack of awareness of nonprofit pharmaceutical companies by the government and the public at large.

Although this report identified 11 companies in the nonprofit pharmaceutical sector, only one was captured in a database of drugs sold in the United States during 2020–2022. The data showed that the volume of sales for this nonprofit pharmaceutical company, which sells 60-plus generic sterile injectables, represented about 2 percent of the total sales volume for the same generics sold by for-profit companies. This finding aligns with stakeholder interviews that indicated that nonprofit pharmaceutical companies currently have limited ability to fill large gaps in the market or create pressure to bring prices down due to their low production volume.

Due to the lack of profit motive, nonprofit pharmaceutical companies have a different risk profile and set of strategies than their for-profit counterparts. Because of this, nonprofit pharmaceutical companies have the potential to increase access to essential and affordable medicines. For example, their strategies to repurpose generics, pick up abandoned products, or bring OTC products to market have partly contributed to pressure on the industry to increase access to low-cost insulin products and to bring OTC naloxone products to market. Further, the focus of nonprofit pharmaceutical companies on low-volume drugs necessitates the conduct of R&D or commercialization activities on essential medicines that for-profit companies may not deem commercially viable.

While nonprofit pharmaceutical companies are governed by a different set of tax laws than for-profit companies, they are subject to the same FDA regulatory requirements and R&D costs to bring products to market. This has led nonprofit pharmaceutical companies to target products that are relatively inexpensive to develop and that have a higher probability of success. Some industry experts do not see nonprofit pharmaceutical companies as disruptors to the industry or as a source of solutions to the issues at hand based on the fact that many of their activities involve relabeling approved products and have low sales volume.

Although nonprofit pharmaceutical companies can leverage their tax-exempt status to seek funding from diverse sources, the complex tax environment sometimes results in a mixed structure of nonprofit and for-profit companies operating under the same organizational umbrella, and this can blur efforts to increase transparency or ensure that drugs are affordable. Though the majority of nonprofit pharmaceutical companies have operational sizes comparable with small businesses, their tax-exempt status makes them ineligible for some types of funding, such as grants from the NIH Small Business Innovation Research program, SBA loans, or even bank loans that require some expected level of revenue. Further, reliance on diverse funding sources can create challenges for nonprofit pharmaceutical companies seeking to align their drug development and commercialization activities with public health priorities.

Through the literature search and stakeholder interviews, we identified a variety of approaches to addressing challenges that nonprofit pharmaceutical companies face. These approaches can be largely divided into financial and nonfinancial incentives. Financial incentives include the establishment of a federal program or set of initiatives that could fund or provide financial support for the development and manufacturing of drugs by nonprofit pharmaceutical companies at all stages of the product life cycle—from early discovery research activities to commercialization—and that could also provide financial support for capital investments. Stakeholders proposed a number of financial incentives tailored to the nonprofit pharmaceutical sector, such as interest-free loans, grants, cooperative agreements, loans not requiring repayment, and advanced purchasing agreements with the government (which would enhance the sustainability of nonprofit companies). Stakeholders and the literature also cited other existing tools that could be leveraged to expand eligibility to the nonprofit pharmaceutical sector, including NIH’s Small Business Innovation Research grants, the Health Resources and Services Administration’s (HRSA’s) 340B Drug Pricing Program, and advanced purchasing commitments from the Strategic National Stockpile.

In addition to the proposed initiatives discussed above, several Congressional bills have been introduced in recent years aimed at the nonprofit pharmaceutical sector. These include Senate Bill 2257, the Expanding Access to Affordable Prescription Drugs and Medical Devices Act, introduced in 2021, which included provisions for funding and low-interest loans to support nonprofit drug development and required FDA user fee waivers. Financial initiatives such as the provisions included in this bill could align eligibility with certain criteria such as manufacturing drugs that are essential, in shortage, or fulfilling a public health need. As an example of the impact of federal funding, some stakeholders cited funding that allowed Civica to begin construction of a manufacturing facility in Virginia. This funding was awarded to Phlow Corporation, a U.S. drug manufacturing PBC, by the U.S. Administration for Strategic Preparedness and Response (ASPR) to build manufacturing capacity of essential medicines in shortage.^70,71^ Stakeholders noted that federal support, in the form of funding or purchase agreements, would help ensure that nonprofit pharmaceutical companies achieve a production volume sufficient to exert pressure in the industry, increase their sustainability and financial stability, and also increase awareness of and trust in the nonprofit pharmaceutical sector. This support could promote market entry, competition, and expansion in this sector.

Existing literature and stakeholders have also proposed non-financial incentives to encourage growth in the nonprofit pharmaceutical sector. Specific examples include expediting FDA review of nonprofit applicant submissions or creating separate regulatory programs for nonprofit pharmaceutical companies. As noted above, regulatory challenges are not specific to the nonprofit pharmaceutical sector. Past studies focused on the for-profit sector have proposed similar solutions (i.e., reduced FDA timelines, simplification of clinical trial protocols, increased interactions with FDA, improved predictability of the review process) to reduce the cost of bringing drugs to market.^72^ FDA already uses existing tools to address drug shortages, including approaches that involve prioritizing and expediting review of certain applications and inspections, providing technical assistance and guidance for small companies,^73^ and authorizing waivers, reductions, exemptions, or refunds of user fees when certain conditions are met.^74^ However, further research is needed to understand how these existing tools can be leveraged to address issues that are specific to the nonprofit pharmaceutical sector.

Through the literature review and discussions with stakeholders, we also identified proposals for using changes to the tax code as a way to lower the entry barrier for nonprofit companies in the pharmaceutical sector. Policy proposals include creating tax incentives that can facilitate the transfer of patents of abandoned drugs, creating incentives for for-profit companies to partner with nonprofit pharmaceutical companies, clarifying the tax code to facilitate activities and funding mechanisms, creating a new tax-exempt designation for nonprofit pharmaceutical companies that are fulfilling a public health need, classifying drug sales of nonprofit pharmaceutical companies as non-taxable revenue, and creating protections to uphold the IRS nonprofit designation. However, stakeholders highlighted the risk of mission drift and oligopoly in the nonprofit pharmaceutical sector if regulations are not implemented to ensure accountability. Literature and stakeholders provided lessons learned from the health care industry, which is dominated by nonprofit health systems, that suggest that the nonprofit model may not always maximize social welfare.

To conclude, while the nonprofit pharmaceutical sector holds promise and can play a role in addressing drug shortages and enhancing access to affordable and essential medicines, more research is needed to understand the available or potential tools that can reduce existing barriers and challenges, as well as understand their implications on competition, drug pricing, and innovation in the pharmaceutical industry.