# Results

## Low-Cost Alternatives to Expensive Drugs

Many life-saving drugs do not have low-cost alternatives, despite being off patent for an extended period. As a result, patients may incur debt or ration their medications, which leads to medication nonadherence and worse health outcomes.^39^ In interviews, stakeholders shared that drug prices are set by for-profit companies to create shareholder value, which is typically achieved by maximizing profit. In contrast, many nonprofit pharmaceutical companies promote the affordability of medical products as a goal in their mission and vision statements. In practice, nonprofit pharmaceutical companies offer a cost-plus model that prices drugs at the level of margins that ensure their sustainability, adding a fixed percentage to the unit cost of each product.

Insulin is an example of a drug for which nonprofit pharmaceutical companies want to provide more alternatives. The global market for insulin is currently dominated by three manufacturers.^39,40^ Almost a year after a nonprofit pharmaceutical company announced its two-year plan to enter the insulin market with prices set at $35 per vial, all three of the for-profit companies cut the out-of-pocket cost to a maximum of $35 per vial.^41–43^ However, the entry of a nonprofit pharmaceutical company into the market was not the only source of competitive pressure. The decision by the for-profit companies to lower insulin prices followed announcements by the state of California that it was going to manufacture its own insulin in partnership with a PBC that operates a cost-plus model. In addition, the Inflation Reduction Act, signed into law in August 2022, capped out-of-pocket costs for insulin at $35 per monthly prescription for Medicare enrollees beginning January 1, 2023.^39,44^

The entry of nonprofit pharmaceutical companies into markets characterized by expensive generic drugs, few manufacturers, and high volume of sales may increase the competitive pressure for all companies to lower their prices. However, drug prices are driven not only by the pricing structures of manufacturers, who seek to capture the cost of R&D, but also by the markups of intermediaries, such as PBMs, wholesalers, and pharmacies. Drug pricing transparency, particularly around negotiated rebates and discounts, has been a topic of debate to increase the public’s understanding of the financial arrangements that affect the profits of stakeholders in the pharmaceutical supply chain. Stakeholders shared that nonprofit pharmaceutical companies are attempting to disrupt persistently high prices for expensive medications by adopting transparency in their financial arrangements as one of their core business strategies. Efforts at providing transparency include disclosing the price and charging the same price for all members, without volume discounts.

Another strategy that nonprofit pharmaceutical companies are adopting to increase competitive pressure is to bring to market over-the-counter (OTC) alternatives to expensive prescription drugs. OTC drugs are typically sold at lower prices than drugs that require a prescription or that are administered in hospitals or physician offices. An example of a nonprofit pharmaceutical company that used this strategy is Harm Reduction Therapeutics, which was inspired to offer an OTC version of naloxone, a life-saving drug used to reverse an opioid overdose, as a way of counteracting price hikes.^45^ Although FDA had encouraged sponsor applications for OTC naloxone products in 2019,^46^ no existing for-profit company had submitted a New Drug Application (NDA) for OTC naloxone until two months after the nonprofit pharmaceutical company submitted its NDA in late 2022.^47,48^ On March 29, 2023, FDA approved the first OTC naloxone product, developed by a for-profit company, and sales began in the summer 2023.^49^ On July 28, 2023, FDA approved Harm Reduction Therapeutics’ ReVIVE, with sales beginning in early 2024.^50^

### Challenges

Nonprofit pharmaceutical companies have limited capacity to offer alternatives for expensive drugs that are not off-patent or are protected by a market exclusivity. While many nonprofit companies contribute to drug discovery and development, they typically leverage partnerships with for-profit pharmaceutical companies to commercialize their products, which creates uncertainties about the pricing model that will be used. For example, although Targretin (bexarotene), a cancer drug, was developed by nonprofit pharmaceutical companies and now has generic competitors available, it was commercialized in partnership with a for-profit company^22^ and is sold for almost $30,000 for 100 capsules.^51^ A related challenge is that the business structure of nonprofit pharmaceutical companies with wholly owned for-profit subsidiaries has the potential to undermine their credibility regarding transparency in drug pricing. One example is CivicaScript, a subsidiary of Civica that was established as a for-profit PBC, which focuses on generic drugs distributed via retail, mail, and outpatient channels for participating pharmacies.^38^

The low levels of therapeutic concentration and market share achieved to date by nonprofit pharmaceutical companies may not be sufficient to disrupt drug pricing in the pharmaceutical market, for multiple reasons. First, stakeholders we interviewed noted that prices of nonprofit pharmaceutical company drugs may not be the lowest in the market at any given time because their prices are designed to create stability in the market and to be the lowest sustainable price for nonprofit pharmaceutical companies (see Drug Shortages for additional discussion). Second, since list prices for drugs do not reflect markups along the pharmaceutical supply chain for each distribution channel, it is difficult to quantify the actual savings for payers and patients when there is a mix in business models. This is especially true for drugs that are administered in hospitals or physician offices because the reimbursements for those drugs are usually bundled with the reimbursements for other services.^52^ Third, while OTC products tend to be low cost, OTC drugs are not covered by health insurance, which may limit patient savings as well as the number and types of patients that could benefit from these drugs.^53^

## Drug Shortages

According to FDA, the majority of drugs in shortage are sterile injectables and older generic drugs with a median time of 35 years since first approval.^54^ Root causes of generic drug shortages are the low profitability of generic drugs and the lack of market rewards for generic manufacturers that invest in quality management maturity; shortages can also occur due to supply chain disruptions or increased demand.^vi^

The nonprofit funding model, which does not expect the same high rates of return for investors, suggests that nonprofit pharmaceutical companies may be able to sell drugs, such as generics, that are associated with low profits. However, just like any organization, nonprofit pharmaceutical companies need to balance their sustainability and cost goals. Some researchers have proposed using the Health Care Utility (HCU) model,^vii^ a novel governance and financing structure, to address drug shortages and persistent price hikes of generic drugs.^55^ The HCU model relies on member^viii^ financing to provide products and services at the lowest sustainable price. Proponents of the HCU model argue that its core tenets address the factors and misaligned incentives that contribute to drug shortages.^6^ The HCU model informed the business structure of Civica Rx, which provides same-price guarantees with no volume discounts, requires long-term commitments, and embeds a quality assurance process in its contracts with CMOs.^36,38^ This pricing approach includes maintaining a six-month buffer supply of its products as a mitigation strategy against drug shortages or supply chain interruptions.^56^ Further, Civica Rx limits its volume agreements to 50 percent of each member’s total volume and establishes contracts with multiple CMOs in North America, Europe, and South Asia to increase the geographical diversity of its suppliers and mitigate supply chain risks.^36^

### Challenges

In interviews, some stakeholders shared that the pricing of products by nonprofit pharmaceutical companies, like Civica Rx, may not be the cheapest on the market because their pricing may account for the cost of investments in quality management systems to mitigate shortages. Stakeholders pointed out that the HCU approach to addressing drug shortages is limited because it provides drugs for members only. The volume of drugs produced by nonprofit pharmaceutical companies may also be too low to have an impact in the broader market. Further, since many nonprofit pharmaceutical companies neither own the license to nor manufacture their own generic drugs, some function like a group purchasing organization (GPO), and as such, they have no control over the price that patients ultimately pay.

Some stakeholders have been skeptical about the feasibility of replicating or scaling up models like the one used by Civica Rx, for multiple reasons. First, long-term contracts may result in members paying a price that is higher than the lowest available market price in the short term, although the price would remain unchanged when there is a shortage. Another risk is the potential to further concentrate bargaining power in one entity and perpetuate the existing oligopoly in the pharmaceutical industry. Stakeholders shared lessons from the health care industry, which is dominated by nonprofit health systems, that suggest the nonprofit model may not always translate to maximizing social welfare. For example, research suggests that nonprofit hospitals are not more likely to provide charity care or unprofitable services than their for-profit counterparts.^57^

## Access to Essential Medicines

FDA, in collaboration with other federal agencies, began developing and publishing a list of essential medicines, medical countermeasures, and critical inputs in 2020 in response to President Trump’s Executive Order on Ensuring Essential Medicines, Medical Countermeasures, and Critical Inputs are Made in the United States.^58^ FDA’s list of essential medicines identifies those medical products that have the greatest potential impact on public health and are most needed by patients for acute and urgent medical conditions. The goal of FDA’s essential medicines list is to ensure that the American public is protected against outbreaks of emerging infectious diseases and chemical, biological, radiological, and nuclear threats by ensuring sufficient and reliable long-term domestic production of these products.^59^ Another list of essential medicines, managed by the World Health Organization (WHO), identifies medications that may be critical to ensuring that a nation’s health system can meet the health care needs of its population. The WHO list of essential medicines prioritizes disease prevalence, public health relevance, and evidence on efficacy, safety, and comparative cost-effectiveness. For this report, we examine the role of nonprofit pharmaceutical companies in addressing gaps in the provision of critical medicines for both chronic and acute health conditions.^60^ For purposes of the stakeholder interviews, essential medicines were broadly defined to include those in the FDA list of essential medicines and others such as oncology drugs or sterile injectables.

In interviews, stakeholders shared that nonprofit pharmaceutical companies could increase access to essential medicines by leading R&D for low-volume medical products to address unmet health needs, such as products focused on rare diseases, neglected tropical diseases, and antimicrobial resistance. Examples of nonprofit pharmaceutical companies engaged in R&D to develop new technologies include Innovative Genomics Institute (IGI), which is working to develop and commercialize CRISPR gene-editing therapies to treat sickle cell disease.^61^ Further, the environmental scan identified that R&D and commercialization for new antibiotics to combat antimicrobial resistance is another market gap that may be appropriate for nonprofit pharmaceutical companies.^62,63^ In comparison to brand-name drugs in other therapeutic areas, new antimicrobials typically have very low volumes and low prices.^64^

Strategies to bring critical medical products to market at lower cost include identifying new uses and indications for approved and off-patent drugs, a strategy known as drug repurposing.^65^ Since safety data exists for approved drugs, it has been estimated that nonprofit pharmaceutical companies can avoid approximately 40 percent of the costs for drug development by repurposing approved drugs.^66^ This strategy can be effective for conditions that have few treatments available, such as rare and neglected diseases. For example, the Institute for One World Health repurposed paromomycin, an off-patent drug that is no longer used as an antibiotic, to cure visceral leishmaniasis, a neglected tropical disease.^ix^

A closely related strategy focuses on rescuing abandoned compounds. These are compounds that for-profit companies researched and developed safety and efficacy data for, but ultimately abandoned before completing development and attaining regulatory approval, typically due to concerns over low profitability. This market gap presents opportunities for nonprofit pharmaceutical companies. In one example, the nonprofit Tutela Pharmaceutical executed an exclusive license agreement for a compound that was abandoned by a for-profit company after the completion of phase 1 and 2 clinical trials.

Another market gap of interest to nonprofit pharmaceutical companies is increasing access to drugs for underserved populations by prioritizing diversity in clinical trials to ensure generalizability of evidence. For example, Medicines360 sponsored a phase 3 clinical trial for the first hormonal IUD that prioritized diversity in the enrollment of clinical trial participants. The company generated safety and efficacy evidence for women of all races, women who had never given birth, overweight or obese women, and women with sexually treated infections—something that wasn’t done for hormonal IUDs that were available on the market at the time.^10^ The environmental scan identified a study that concluded that patients at a Title X clinic experienced increased uptake and decreased average payments after the introduction of Medicines360’s hormonal IUD.^67^ This was the only example we identified of a nonprofit pharmaceutical company successfully developing and commercializing a branded medical product for the U.S. market. While this nonprofit pharmaceutical company retained ownership of the NDA, commercialization of the medical product occurred through a licensing agreement with a for-profit company. In exchange for licensing the intellectual property of the nonprofit pharmaceutical company, the for-profit company committed to prioritizing commercialization of the hormonal IUD, paid an upfront payment and milestone payments, and paid continuous royalties on units sold, which are non-taxable because they are not classified as unrelated business income.^10^ Retaining ownership of the license allowed Medicines360 to maintain ownership of the drug and reinvest in R&D to identify new indications. Stakeholders noted that entry by Medicines360 for an underserved market spurred additional investment and development of new products by for-profit companies. Other strategies that nonprofit pharmaceutical companies have adopted to launch their products include creating wholly owned for-profit subsidiaries, entering into partnerships with PBCs, or selling the license to a for-profit pharmaceutical company. However, as noted above, these types of partnerships or business structures have the potential to undermine their credibility regarding transparency in drug pricing.

### Challenges

Nonprofit pharmaceutical companies face challenges with repurposing off-patent drugs and rescuing abandoned compounds, including difficulty raising capital to conduct expensive phase 3 clinical trials and aligning with donor priorities.^66^ For example, disulfiram, a drug approved as an anti-alcoholism medication, has been proposed as a candidate to be repurposed to treat many diseases, including various cancers, Alzheimer’s disease, and COVID-19.^66,68^ However, in such circumstances, nonprofit pharmaceutical companies must consider the interests of their donors as they prioritize which potential new indications to pursue. While donors may prioritize public benefits, it is unclear that their priorities will always align with public health needs that maximize social welfare.

Further, the risk of donor fatigue undermines the long-term sustainability of the nonprofit model. Pull incentives, wherein the government aims to reward new drug development for underserved markets by reducing the risk of insufficient future revenue streams through higher reimbursement policies, have been successfully employed to develop new hospital-based antibiotics. For example, the Centers for Medicare & Medicaid Services (CMS) have paid new technology add-on payments for novel antibiotics used in the inpatient setting.^69^ However, oftentimes sales revenue from antibiotics cannot sustain a company’s infrastructure costs, so other investments unrelated to sales revenue would also be necessary to ensure the sustainability of the nonprofit model for companies developing antibiotics or other low-volume medical products.^64,69^

Beyond R&D costs, nonprofit pharmaceutical companies need to raise funds for complex commercialization activities, such as manufacturing, distribution, reimbursement, and post-marketing commitments. If a company’s nonprofit tax-exempt status was obtained based on a mission to conduct research, then its sales revenue from commercialized medical products may be subject to business income taxes. In addition, stakeholders shared that commercial activity by nonprofit pharmaceutical companies may attract litigation and jeopardize tax-exempt status under the IRS “commerciality” doctrine.^x^ Stakeholders also noted that FDA has limited experience working with nonprofit pharmaceutical companies, who may also not be aware of flexibilities available to them.

Nonprofit pharmaceutical companies adopt several strategies to navigate the complex pharmaceutical supply chains in the United States and retain tax-exempt status. However, some of these strategies may not be feasible for low-volume products. In one example, stakeholders shared that a nonprofit pharmaceutical company regained ownership of a gene therapy that was licensed to a for-profit company, likely because of claw-back clauses^xi^ in the licensing agreement. For several years after gaining the license for the gene therapy, the for-profit company had been unable to meet the comparability^xii^ requirement to scale it, and the company had ultimately terminated related development activities. While the gene therapy may be available to patients through the compassionate use program, shareholders stated that nonprofit pharmaceutical companies may not have the financial resources and expertise required to launch phase 3 trials, pay FDA user fees, maintain all of the regulatory requirements to obtain FDA approval, or meet manufacturing requirements for widespread distribution without a commercial for-profit partner.

## Limitations

This report has several limitations. First, the stakeholder interviews were limited to nine experts, and as such, the findings from this report may not be generalizable to all stakeholders impacted or involved. For example, the stakeholder interviews included a limited number of experts from the for-profit pharmaceutical industry. Further, although the environmental scan aimed to include broad terms, it is possible that our search terms and results did not capture other key topics or issues. Lastly, given the nascent nature of this sector, there was limited availability of data to quantitatively examine the role of the nonprofit pharmaceutical companies in increasing the supply of essential and affordable drugs.

vi Quality management maturity measures the consistency and reliability of business processes to assure and maintain the quality of products in the marketplace, including early signals to enable actions to prevent drug shortages triggered by quality issues.

vii Utility is a reference to commonly shared basic goods, such as electricity and gas.

viii Members are customers of the HCU; for example, health systems are the customers for hospital-based drugs and health insurance companies are customers for retail drugs. Some call the HCU a “closed-system” model because only members have access to the products and services.

ix It is worth noting that NIH’s National Center for Advancing Translational Sciences created a drug repurposing program intended to facilitate sharing of data and other resources for scientists and others interested in repurposing drugs. See https://sites.google.com/ncats.nih.gov/therapeutic-repurposing/home.

x In its [underlined: determination] that a business entity did not qualify as a 501(c)(3) organization, IRS stated “factors courts have considered in assessing commerciality are competition with for-profit commercial entities; extent and degree of below cost services provided; pricing policies; and reasonableness of financial reserves.”

xi Claw back is a contractual provision that allows an instance of recovering assets or benefits previously given out.

xii Comparability requirement means demonstrating that phase 2 results are comparable to phase 3 results.