# Background

## Brief History of Nonprofit Companies in the Pharmaceutical Industry

Nonprofit companies are tax-exempt^i^ economic entities organized around missions or objectives intended to further a social cause or provide a public benefit. Nonprofit companies differ from the traditional for-profit business model, which aims to maximize profit for investors. Nonprofit companies are restricted from distributing profits to any private shareholder or individual.^13^ They leverage their social mission to attract donations from private entities or funding from public entities to finance the provision of their goods and services. Many sectors, such as pharmacies, hospitals, hospices, nursing homes, and home health care, are structured with a mix of nonprofit and for-profit companies. The literature examining non-pharmaceutical sectors suggests that the co-existence of nonprofit and for-profit companies can promote competition and increase access to services for consumers.^14–16^ However, little is known about the benefits and implications of these two models in the pharmaceutical industry.

Although the pharmaceutical industry is dominated by for-profit companies, nonprofit companies have a long history of advancing innovation in this industry.^17–20^ The majority of their contributions have occurred through R&D activities,^21,22^ sponsored by funding from public and private entities. Some nonprofit companies independently conduct R&D with their endowments, royalties, donations, or other funding, while others partner with outside entities leading these activities. Philanthropic nonprofits,^ii^ such as the Bill & Melinda Gates Foundation and CureDuchenne, may also fund sponsored targeted R&D projects with nonprofit and for-profit companies.

Typically, nonprofit companies have not pursued commercialization activities, such as obtaining market authorization from the U.S. Food and Drug Administration (FDA) and manufacturing and distributing pharmaceutical products.^8,17,23^ The dominant approach has been for nonprofit companies to license new drugs from their R&D pipeline to for-profit companies.^8^ Some experts have pointed out that this approach can result in negative consequences: nonprofit companies lose the right to manufacture their drugs exclusively, and for-profit companies launch new drugs with the goal of maximizing profits, which may result in high prices for consumers. For example, the Cystic Fibrosis Foundation (CFF), a philanthropic nonprofit organization, invested $150 million in a for-profit company to develop ivacaftor, the first drug to address the underlying cause of cystic fibrosis.^24^ CFF then sold the royalty rights to ivacaftor for $3.3 billion to a different for-profit company.^25^ The list price for ivacaftor when it was licensed in 2012 was $294,000 per patient per year.^26^ In 2019, a new combination product, Trikafta (elexacaftor/ivacaftor/tezacaftor), was released with an average list price of $322,000 per patient per year.^27^ Other examples of innovative and expensive drugs that were initially developed or financed by nonprofit companies and then were licensed to for-profits for commercialization include voretigene neparvovec for congenital blindness, tisagenlecleucel for leukemia, and bexarotene for lymphoma.^8,20^ While non-exclusive licenses have been cited as an alternative, it is worth noting that licensors must also weigh factors such as costs or profitability to determine the terms of the license. For-profit pharmaceutical companies have also used business strategies such as licensing, mergers, and acquisitions to obtain access to new drugs. Researchers have reported that the share of revenues coming from innovations sourced outside of for-profit companies has grown from 25 percent in 2001 to about 50 percent in 2016.^28,29^

In this report, we focus on nonprofit companies that are pursuing commercialization activities in the pharmaceutical industry.

## Profile of Nonprofit Pharmaceutical Companies, 2000-2022

Table 1 provides a profile of nonprofit pharmaceutical companies that entered the market between 2000 and 2022. The information in the table points to a sector that is largely fragmented. The environmental scan conducted for this report identified 11 nonprofit pharmaceutical companies in the U.S. market that met our definition. Their specific mission statements ranged from providing affordable medications to enhancing access to essential medicines or those in shortage, though each mission statement identified product commercialization as one of the company’s goals. Further, the environmental scan revealed variation with respect to the types and number of products nonprofit pharmaceutical companies provide—some focus on a specific treatment area with a handful of products, while others provide dozens of products across multiple therapeutic areas.

The nonprofit pharmaceutical companies also differ in their operations. Some engage in R&D for product development and commercialization. For example, Medicines360 engaged in R&D and commercialization of its hormonal intrauterine device (IUD), which is accessible to low-income women in public clinics across the United States.^10^ (This case is discussed in more detail in Access to Essential .) In other cases, nonprofit pharmaceutical companies focus only on commercialization activities, such as manufacturing, distribution, and relabeling. For example, Drew Quality Group launched in 2014 with the mission to become a supplier of high-quality generic drugs that are manufactured in the United States.^30^ As of March 2023, the environmental scan and key stakeholder interviewers suggest that Drew Quality Group has not yet achieved this objective. Another example is Civica, which entered the market in 2018 with a focus on relabeling and distribution of generic sterile injectables.^31^ While there is no one-size-fits-all approach, a common theme is the expressed desire to promote the affordability of drugs and broaden access to pharmaceutical products by engaging in commercialization activities.

All the nonprofit pharmaceutical companies we identified have an Internal Revenue Service (IRS) tax-exempt status as either a 501(c)(3) charitable organization^32^ or a 501(c)(4)^iii^ social welfare organization.^33^ Among the 501(c)(3) charitable organizations, some are designated as public charities rather than as private foundations.^iv^ We examined the most recent IRS form 990 for each of the nonprofit pharmaceutical companies^34^ and found that all of them reported annual revenues below $20 million, with the majority reporting annual revenues below $2 million. All the nonprofit pharmaceutical companies also reported negative annual net income, indicating expenses exceeded revenues. In contrast, research suggests that from 2000 to 2018, 35 large for-profit pharmaceutical companies reported median annual revenue of $10.6 billion and median net income of $1.1 billion.^35^ While nonprofit pharmaceutical companies tend to be comparable to small businesses based on their revenues or number of employees, the literature and many stakeholders noted that their tax-exempt status does not make them eligible for certain types of funding, such as Small Business Innovation Research grants from the National Institutes of Health (NIH), Small Business Administration (SBA) loans, or even bank loans that require some expected level of revenue.

Table 1 Nonprofit Pharmaceutical Companies in the United States, 2000–2022

Name (Year Founded) | Total Revenue (Year) | Mission Statement | Conditions or Drugs Targeted | Current Drugs in U.S. Market | Associated Companies
Civica Inc. (2018) | $16,726,911, as of 2019 | Provide quality generic medicines that are available and affordable to everyone. | Various conditions requiring generic sterile injectables; insulin for diabetes | Civica Rx is involved in private labeling and distribution of 60 generic sterile injectables; CivicaScript is distributing abiraterone—used to treat prostate cancer—and plans to distribute three low-priced generic insulin products by 2024. | Civica Rx, CivicaScript, and Civica Foundation. While Civica Rx focuses on generic drugs used in the hospital setting, CivicaScript, a public benefit company (PBC),^v^ works with pharmacy benefits managers (PBMs) and insurers to bring low-cost generics to outpatient and retail pharmacies. The Civica Foundation is a 501(c)(3) organization that provides philanthropic support to manufacture and distribute generic medications.
Drew Quality Group (2014) | less than $50,000, as of 2021 | Improve society’s health by being a supplier of high-quality generic drugs, manufactured in the United States. | Generic drugs | None | N/A
Fair Access Medicines (2015) | less than $50,000, as of 2021 | Identify, develop, and deliver life-saving medicines to poorly served patients in the United States and worldwide at the lowest cost possible. | Insulin for diabetes | None | N/A
Harm Reduction Therapeutics (2017) | $1,550,000, as of 2019 | Make naloxone more accessible for everyday people by combining increased funding, generating more interest in public health, and building on our years of expertise. | Naloxone for opioid overdose | None. Over-the-counter naloxone product approved in July 2023, with an expected launch date in early 2024. | N/A
Institute for Pediatric Innovation (2006) | $34,443, as of 2020 | Research and develop innovative products that will improve the health of children and support those who provide care for them. | Pediatric conditions | None. Mission focus has evolved to focus on digital health. | N/A
Medicines360 (2009) | $17,400,453, as of 2019 | Catalyze equitable access to medicines and devices through product development, policy advocacy, and collaboration with U.S. and global partners. | Contraception, such as hormonal lUDs | One branded hormonal IUD, Liletta, through Actavis; over-the-counter emergency contraceptive through Curae Pharma360. | Medicines360’s subsidiary is Curae Pharma360 Inc. which is a for-profit organization focused on improving the availability of quality generic drugs and other medicines that are in short supply. Medicines360 selected Actavis (formerly Watson Women’s Health, then Allergan, and now AbbVie) as its for-profit commercial partner for a hormonal IUD.
NP2 (2019) | $340,500, as of 2020 | Promote public health by developing, manufacturing, and distributing medicines for the treatment of life-threatening diseases in underserved populations. | Generic drugs for cancer | None | N/A
Odylia (2018) | $60,528, as of 2020 | Accelerate the development of gene therapies for people with rare disease, changing the way treatments are brought from the lab to the clinic...to bring life-changing treatments to people with genetic disease regardless of prevalence or commercial interest. | Gene therapies for rare genetic disorders | None | Odylia has partnered with Cloves Syndrome Community, SATB2 Gene Foundation, Usher 2020 Foundation, RDH12 Fund for Sight, and PTC Therapeutics.
Institute for One World Health \| PATH Drug Solutions (2000) | $2,972,163, as of 2018 | Develop and deliver lifesaving medicines to women, children, and communities around the globe. | Drugs and vaccines for various infectious diseases, contraception, and maternal and child health | An injectable contraception, subcutaneous depot medroxyprogesterone acetate (DMPA-SC), through Pfizer. | PATH selected Pfizer as its for-profit commercial partner for an injectable contraception.
Remedy Alliance Inc. (2012) | $95,600, as of 2021 | Ensure harm reduction programs have sustainable & equitable access to low-cost naloxone for distribution in their communities. | Naloxone for opioid overdose | Remedy Alliance is involved in the distribution of generic naloxone. | N/A
Tutela Pharmaceutical (2020) | Less than $50,000, as of 2021 | Ensure continued and affordable access of single-source medications to patients. | Single-source medications subject to discontinuation or divestiture by their manufacturers | None. Acquired license from Astellas Pharma Inc. for active ingredient of a medication previously tested for COVID-19. | Collaborators include Zensights, Pharmafusion, Tucker Ellis, LLP, Incubate IP, and Godfrey & Kahn, SC.

Note: All general information obtained from company websites; financial information was obtained through IRS.gov.

Table 2 presents the number of products, sales, and units sold for the only nonprofit pharmaceutical company, Civica, identified in IQVIA’s NSP dataset from 2020 to 2022, as well as the corresponding statistics for for-profit companies showing sales and units sold for the same products. The data show that Civica sold 350 million units of 64 products for $256 million in sales. We identified 88 for-profit companies with a total of 20.2 billion units sold and $13.9 billion in sales for the same products, suggesting that sales for the one nonprofit pharmaceutical company represents about 2 percent of total sales and volume for these products.

Table 2 Descriptive Statistics by Pharmaceutical Sector, United States, 2020–2022

Description | Nonprofit | For-profit
Number of companies | 1 | 88
Number of products | 64 | 64
Total units sold | 350.2 million | 20.2 billion
Total sales | $255.9 million | $13.9 billion

Note: A product is defined as a molecule-form-strength combination.

Source: ASPE analysis of IQVIA National Sales Perspective data.

## Market Growth

Growth in the nonprofit pharmaceutical sector was slow between 2000 and 2016 with one firm entering the market every three years, on average. Most of the growth in this sector occurred over the five years that followed; on average, one nonprofit pharmaceutical company entered the market each year during 2017-– 2021. Out of the 11 identified companies, two are no longer operating as originally envisioned (we consider these market exits), and one merged with a global nonprofit company in 2011 (Figure 1). As of August 2023, five of the 11 nonprofit pharmaceutical companies had either received FDA marketing authorization or were distributing medical products in the United States.

The majority of nonprofit pharmaceutical companies were either in the R&D phase of medical product development or looking to secure start-up capital. As discussed above, most nonprofit pharmaceutical companies have historically outsourced the manufacturing, packaging, and labeling of their medical products to contract manufacturers. However, one nonprofit pharmaceutical company, Civica, has exhibited noticeable growth since its creation in 2018. Civica offers over 60 generic sterile injectable medications to over 1,500 hospitals through Civica Rx.^36^ Further, in 2021, Civica created CivicaScript, a PBC, to offer generic drugs used in the outpatient and retail settings.^37^ The Civica Foundation was also established to provide philanthropic support to manufacture and distribute generics. Civica’s rapid growth has been credited to its ability to leverage the long-term commitments of its hospital and health system members to secure long-term supply contracts.^38^ These supply contracts have incentivized the reentry of numerous contract manufacturing organizations (CMOs) that had excess capacity and held many of the Abbreviated New Drug Applications (ANDAs) for generic drugs that Civica now labels and distributes to its members.

Figure 1 Market Growth Timeline, Nonprofit Pharmaceutical Industry, United States, 2000–2022

*Market exit refers to a shift in mission or operations that no longer covers commercialization activities.

Timeline from 2000 to 2022 showing the following market growth events: first U.S. nonprofit pharma enters in 2000, 3 market entries between 2000 and 2010, 3 market entries, 1 merger, and 1 exit between 2011 and 2016, 5 market entries and 1 exit between 2017 and 2022. Label on 2022 indicating 9 total nonprofit pharma.

## Market Entry Strategies

Nonprofit pharmaceutical companies generally begin operations with funding from philanthropic entities or individuals, including crowdsourcing, that support their mission statement. In contrast, for-profit companies depend on raising funds through investors who expect a return on their capital. Without the expectation to sell pharmaceutical products that generate high profit, nonprofit pharmaceutical companies have a different risk tolerance and may be able to provide products with low or negative profit. However, both for-profit and nonprofit pharmaceutical companies face similar costs, timelines, and regulatory oversight when developing and bringing products to market, and both generate revenue from selling drug products and services.

Typically, nonprofit pharmaceutical companies focus on a single product when entering the market. Since they must demonstrate that their mission is compelling enough to motivate access to philanthropic funding, nonprofit pharmaceutical companies tend to be organized around addressing intractable market gaps to improve social welfare—for example, by increasing access to medicines at affordable prices, mitigating drug shortages, or developing new drugs for rare or tropical diseases.

When selecting their target drugs, nonprofit pharmaceutical companies, like their for-profit counterparts, consider multiple factors, such as the target market size, start-up costs, regulatory requirements, and the sustainability of their business model. In interviews, stakeholders noted that nonprofit pharmaceutical companies may prefer to focus on niche drugs such as those with low start-up costs, low margins, or high volumes. Some niche markets that nonprofit pharmaceutical companies have entered are:

○ Essential drugs or drugs in shortage: Enhancing access to affordable medications, essential or lifesaving medications, and medications that experience persistent shortages is part of the mission of many nonprofit pharmaceutical organizations. This mission can also engender trust in the market as nonprofit pharmaceutical companies begin to be recognized for filling gaps in market demand and meeting unmet medical needs.
○ Generics: By targeting off-patent drugs, nonprofit pharmaceutical companies can focus on products that are typically associated with low margins, as well as lower start-up, development, and regulatory costs and lower litigation risks. These products are generally not attractive to for-profit companies due to the low margins and intense pressure to keep prices down via competition.
○ Discontinued drugs: Nonprofit pharmaceutical companies can fill treatment gaps by focusing on medical products that have been discontinued or abandoned by for-profit companies due to low volume and profitability. These drugs represent opportunities for nonprofit pharmaceutical companies to enter the market.
○ High-volume drugs: By targeting high-volume products like insulin, nonprofit pharmaceutical companies ensure the market can facilitate competition and business sustainability. Some of these high-volume drugs have experienced persistently high prices, despite being off patent.

i In some circumstances, nonprofit companies are subject to taxes, such as taxes on unrelated business taxable income (UBTI).

ii Philanthropic nonprofits may invest in R&D with for-profit pharmaceutical companies.

iii 501(c)(4) social welfare organizations differ from 501(c)(3) charitable organizations in that donations or contributions to a 501(c)(4) organization are not tax-deductible on federal tax returns for the entity making the donation.

iv Private foundations have lower levels of public involvement and scrutiny in their activities than public charities. While public charities typically receive a greater portion of their funding from public sources, private foundations are typically controlled by small groups of individuals, such as family members.

v Public benefit companies are for-profit entities that maintain profit and public benefit objectives.