# Methodology

The Office of the Assistant Secretary for Planning and Evaluation (ASPE) used a qualitative methods approach that included both an environmental scan and key stakeholder interviews. NORC, under contract with ASPE, conducted the preliminary searches and key stakeholder interviews.

## Defining Nonprofit Pharmaceutical Companies

Nonprofit pharmaceutical companies are tax-exempt entities that have an established presence in the pharmaceutical industry, typically pursuing R&D activities and licensing new drugs to for-profit companies. In this report, we define a nonprofit pharmaceutical company as a tax-exempt entity with a publicly disclosed goal of pursuing market authorization and commercialization of drugs to deliver low-cost medicines, including essential drugs and drugs in shortage, and broadening access to medical products. This excludes nonprofit companies that may invest in drug development to secure licensing agreements with for-profit companies and nonprofit companies that provide contract services (e.g., contract development manufacturing organizations [CDMOs]).

## Environmental Scan

The environmental scan used a list of primary and secondary search terms to identify peer-reviewed and grey literature relevant to the topic areas of interest: the nonprofit pharmaceutical sector, low-cost alternatives to expensive medications, drug shortages, and access to essential medicines. The initial search terms included keywords such as (“nonprofit pharmaceutical company” OR “nonprofit biopharmaceutical sector”) AND (“generic drugs” OR “low-cost alternatives”). Appendix B lists the search terms used for the preliminary searches conducted by NORC. The inclusion criteria included materials published in English between 2000 and January 2023. In addition, ASPE supplemented the preliminary searches conducted by NORC using a “snowball” approach to identify other relevant information.

Further, we cross-referenced the list of nonprofit pharmaceutical companies generated from the environmental scan with the IQVIA National Sales Perspective (NSP) dataset to gather market information such as the number of products and total sales from January 2017 to December 2022. For the identified products sold by nonprofit pharmaceutical companies in the IQVIA NSP dataset, we compared the sales volume of those products sold by the nonprofit pharmaceutical sector with the for-profit pharmaceutical sector. We note that this search resulted in the identification of one nonprofit pharmaceutical company, Civica, which indicates that this is the only nonprofit pharmaceutical company marketing products in the United States during the period of analysis.

## Key Stakeholder Interviews

To supplement the environmental scan, NORC facilitated nine (9) interviews with key informants with expertise in addressing drug shortages, increasing access to essential medicines, or providing low-cost alternatives to expensive medications. Key informants were affiliated with nonprofit and for-profit pharmaceutical companies, academic institutions, and hospitals.