# Introduction

Americans rely on medical products, such as prescription drugs, to prevent or treat acute and chronic diseases. However, persistent high prices and shortages threaten access to lifesaving therapeutics and pose a risk to the capacity of America’s health system to effectively mitigate and respond to public health emergencies and ongoing public health issues.^1,2^ These market gaps in the pharmaceutical industry have prompted a number of companies with alternative business models to enter the market, including nonprofit pharmaceutical companies, which are launched with any specified purpose other than making a profit.

The prevailing business model in the pharmaceutical industry is oriented toward the pursuit of the next blockbuster drug, defined as a drug with $1 billion or more in annual global sales.^3^ For-profit companies may utilize their profits to reinvest in research and development (R&D) or deliver a high return on investment to shareholders. However, critics argue that the blockbuster model in the pharmaceutical market incentivizes a non-innovative culture that results in duplicative and nonproductive ventures targeted to populations where high revenues are guaranteed.^4^ Further, some researchers have indicated that prioritizing the development of blockbuster drugs contributes to higher prices and unmet public health needs, such as shortages of older generics and underinvestment in R&D for new antibiotics and drugs for certain rare diseases.^3–6^ Researchers have proposed alternative business models to promote growth in the nonprofit pharmaceutical sector and address some of the existing market gaps.^7–10^ These alternative business models include nonprofit collaborations with for-profit companies to increase manufacturing and distribution capacity, creation of nonprofit manufacturing and distribution companies, and partnering with other stakeholders to strengthen existing capability and expertise. (See Appendix A for a detailed summary of the alternative economic models that have been proposed in the literature.)

While the emergence of nonprofit companies to address market failures is not a new phenomenon in non-pharmaceutical markets,^11^ there has been growing interest, including from Congress,^12^ in understanding whether nonprofit pharmaceutical companies could offer solutions to the challenges of drug access and affordability.^8^ Drawing from an environmental scan of the literature and key stakeholder interviews, this report examines the ways in which nonprofit pharmaceutical companies can address a number of existing gaps, including their potential role in reducing drug shortages, increasing access to essential medicines, and providing low-cost alternatives to expensive medications.