# Key Points

○ We identified 11 nonprofit pharmaceutical companies that launched between 2000 and 2022 with mission statements aimed to enhance access to affordable and essential drugs or resiliency in the supply chains of medical products.
○ Some of these nonprofit pharmaceutical companies owned for-profit subsidiaries as a strategy to navigate a complex tax system; the majority did not have any medical products in the domestic pharmaceutical marketplace, none of them owned their own manufacturing facilities, and their financial statements suggested these tax-exempt companies were comparable in scale to for-profit small businesses and start-up companies.
○ Two nonprofit pharmaceutical companies that have successfully launched medical products in the United States used different strategies for commercialization, including using contract manufacturing organizations for labeling and distribution and entering into a licensing agreement with a for-profit pharmaceutical company.
○ Findings suggest that while nonprofit pharmaceutical companies hold promise in addressing drug shortages and enhancing access, their capacity and sustainability may be limited due to low production volumes, uncertainties about funding, and inexperience navigating complex tax, regulatory, and reimbursement systems.