# Appendix B Environmental Scan Search Terms

Primary Search Terms | Secondary Search Terms
Nonprofit pharmaceutical company | Cost/Costly/High Cost
Pharmaceutical public benefit corporation | Price
Nonprofit pharmaceutical sector | Affordability
Nonprofit pharmaceutical market | Low-cost generic drugs
Nonprofit biopharmaceutical company | Low-cost alternatives
Biopharmaceutical public benefit corporation | Low-cost substitutes
Nonprofit biopharmaceutical sector | Low-cost biosimilars
Nonprofit biopharmaceutical market | Reimbursement
Biotechnology | Payers
Nongovernmental pharmaceutical company | Access
Charitable organizations | Drug shortage
Tax-exempt organizations | Essential drugs/medications
| Life-threatening disease/rare disease
| Life-saving medication
| Critical drugs
| Public health emergency
| Orphan drugs
| Specific Drugs
| Antibiotics/antibacterials/antimicrobials
| Saline
| CNS drugs