# Appendix A Alternative Economic Models for Commercialization by Nonprofit Pharmaceutical Companies

Several alternative economic models have been proposed in the literature to promote market authorization and commercialization by nonprofit pharmaceutical companies in the marketplace. Three of them are summarized below.

## Nonprofit pharmaceutical companies as market authorization holders leveraging the manufacturing and distribution expertise of for-profit companies

Existing literature has proposed that nonprofit pharmaceutical companies could expand their organizational capacity to pursue market authorization of new products discovered through their R&D pipeline rather than license the intellectual property or engage in mergers and acquisitions.^8,9,23^ In this model, nonprofit pharmaceutical companies would leverage the expertise of for-profit pharmaceutical companies to maximize efficiency in production and distribution.^8^ For example, nonprofit pharmaceutical companies could license new products to multiple for-profit companies for manufacturing and distribution. Further, the partnership agreements could include clauses to ensure social welfare outcomes, such as affordability and access for underserved populations, and balance sustainability against the need to generate profits. Proponents of this model state that this strategy could ensure that pricing is guided by drug affordability goals.

An important challenge to scaling up this strategy is that nonprofit pharmaceutical companies may not have the expertise or financial resources to navigate clinical development activities, such as phase 3 clinical trials. Another challenge is ensuring that a nonprofit pharmaceutical company is accountable to its core mission and will not engage in misaligned actions, such as price-gouging. Participation on the board of trustees by major donors and patients, who have a financial interest in drug affordability and accessibility, may mitigate this risk.^6^

Medicines360 demonstrated the viability of this concept with the commercialization of its hormonal IUD in the United States.^10^ The product was initially launched with an $82 million grant from a private philanthropic nonprofit. The total cost, including product liability insurance, of bringing the hormonal IUD to market was $73.4 million. Medicines360 partnered with Actavis, a for-profit company. However, Medicines360 retained its rights to market the hormonal IUD at a deeply discounted price to public clinics and hospitals, such as federally qualified health centers, throughout the United States. Similarly, Medicines360 retained marketing rights to sell the hormonal IUD in low- and middle-income countries.

## Nonprofit pharmaceutical companies as market authorization holders with in-house manufacturing and distribution expertise

In this model, nonprofit pharmaceutical companies would expand their organizational capacity to manage all commercialization activities, including manufacturing and distribution.^8,9^ An important barrier to adopting this approach is the high start-up costs for new nonprofit pharmaceutical companies that do not have the ability to leverage the economies of scale of established for-profit companies. This is a particular problem for low-volume and new pharmaceutical products. One solution is for nonprofit pharmaceutical companies to modify this approach by outsourcing actual production to CMOs. Another solution would involve selling exclusive licensing of some products to raise start-up capital for internal commercialization of other products.^8^

Proponents state that this strategy could be appropriate for nonprofit pharmaceutical companies that want to target drugs that are not costly to bring to market, such as old generic drugs that have low profits and experience frequent shortages.^6^ The ANDA process to obtain market authorization for old generic drugs is less expensive because some of the regulatory requirements can be fulfilled with existing data on efficacy and safety. An ASPE analysis found that the average cost to develop a generic drug was $2.4 million ($3.2 million in 2022 dollars) and the time required to bring the product to market was just under five years.^75^

One example of a nonprofit pharmaceutical company demonstrating the viability of this model for old generic drugs is Civica.^38^ As of March 2023, Civica Rx was distributing 60 generic sterile injectables to its members in the United States through its supply contracts with foreign and domestic CMOs. Civica is in the process of expanding to outpatient and retail pharmacies through CivicaScript. While Civica currently relies on ANDAs of its CMOs, it plans to obtain its own ANDAs for generic drugs, such as insulin, and is building a manufacturing facility in Virginia.^36,38^

## Nonprofit pharmaceutical companies leveraging product development partnerships

Nonprofit Product Development Partnerships (PDPs) are another model that has proven successful for launching affordable and accessible medical products. PDPs coordinate financial and development efforts for medical product development in partnership with for-profits, nonprofits, and public stakeholders. For example, the Global Alliance for TB Drug Development (TB Alliance) received FDA approval for pretomanid to treat extensively drug-resistant tuberculosis. TB Alliance negotiated license agreements to ensure access in low-income countries.^76^ Nonprofit PDPs have succeeded in bringing many medical products to market that address unmet public health needs in low- and middle-income countries.^77^ PATH, a U.S.-based nonprofit, obtained FDA approval and commercialized depot medroxyprogesterone acetate (DMPA-SC), an injectable contraceptive, for the domestic market through a PDP.^77,78^ Joint academic-industry-government alliances to foster collaboration are also common in the United States and have similar objectives to those of PDPs.^79^ However, they are not formally incorporated.