# References

Allen, J., Bergman, K., Bruinooge, S., Davis, A., Downs, C. G., Ferris, A., Fleury, M., Fredette, P., Hirsch, B., Hofacker, J., Lichtenfeld, L., Lubejko, B., Massett, H., McKee, A., Michaels, M., Minasian, L., Patrick-Lake, B., Purvis, J., & Puckrein, G. A. (2018). Barriers to Patient Enrollment in Therapeutic Clinical Trials for Cancer: A Landscape Report. https://www.fightcancer.org/sites/default/files/Nationalpercent20Documents/Clinical-Trials-Landscape-Report.pdf (https://www.fightcancer.org/sites/default/files/National%20Documents/Clinical-Trials-Landscape-Report.pdf)
Andring, L. M., Corrigan, K. L., Rooney, M., Bailard, N., Domingo, M., Fellman, B., Varkey, J., Foster-Mills, T., Kazantsev, T., Lin, L., Jhingran, A., Colbert, L., Eifel, P., Klopp, A. H., & Joyner, M. (2023). Patient Reported Outcomes for Women Undergoing Definitive Chemoradiation for Gynecologic Cancer: A Prospective Clinical Trial. Practical Radiation Oncology, S1879–8500(23)00224–2. 10.1016/j.prro.2023.07.004
Bangs, R., & Crispino, T. (2019). From the other side: The patient perspective on cancer clinical trials. Urologic Oncology, 37(5), 331–335. 10.1016/j.urolonc.2018.01.003 29428573
Barrett, N. J., Hawkins, T. V., Wilder, J., Ingraham, K. L., Worthy, V., Boyce, X., Reyes, R., Chirinos, M., Wigfall, P., Robinson, W., & Patierno, S. R. (2016). Implementation of a Health Disparities & Equity Program at the Duke Cancer Institute. Oncology Issues, 31(5), 48–57. 10.1080/10463356.2016.11884124
Bierer, B. E., White, S. A., Gelinas, L., & Strauss, D. H. (2021). Fair payment and just benefits to enhance diversity in clinical research. Journal of Clinical and Translational Science, 5(1), e159. 10.1017/cts.2021.816 34527298
Blinder, V. S., Deal, A. M., Ginos, B., Jansen, J., Dueck, A. C., Mazza, G. L., Henson, S., Carr, P., Rogak, L. J., Weiss, A., Rapperport, A., Jonsson, M., Spears, P. A., Cella, D., Gany, F., Schrag, D., & Basch, E. (2023). Financial Toxicity Monitoring in a Randomized Controlled Trial of Patient-Reported Outcomes During Cancer Treatment (Alliance AFT-39). Journal of Clinical Oncology: Official Journal of the American Society of Clinical Oncology, 41(29), 4652– 4663. 10.1200/JCO.22.02834 37625107
Bodurtha Smith, A. J., Pena, D., & Ko, E. (2022). Insurance-Mediated Disparities in Gynecologic Oncology Care. Obstetrics and Gynecology, 139(2), 305–312. 10.1097/AOG.0000000000004643 34991133
Borno, H. T., Zhang, L., Siegel, A., Chang, E., & Ryan, C. J. (2018). At What Cost to Clinical Trial Enrollment? A Retrospective Study of Patient Travel Burden in Cancer Clinical Trials. The Oncologist, 23(10), 1242–1249. 10.1634/theoncologist.2017-0628 29700209
Borno, H. T., Zhang, L., Zhang, S., Lin, T. K., Skafel, A., Nieves, E., Dornsife, D., Johnson, R., Rhoads, K., Small, E., & Spicer, D. (2022). Implementation of a Multisite Financial Reimbursement Program in Cancer Clinical Trials Integrated With Patient Navigation: A Pilot Randomized Clinical Trial. JCO Oncology Practice, 18(6), e915–e924. 10.1200/OP.21.00328 35196064
Borno, H. T., Zhang, S., Lin, T. K., Zhang, L., Palmer, N. R., Nguyen, C., Kaplan, C., & Ryan, C. J. (2022). Evaluating the impact of financial toxicity among cancer clinical trial participants. International Journal of Cancer Care and Delivery, 2(1). 10.53876/001c.30796
BrintzenhofeSzoc, K., Canin, B., Casas-Silva, E., Denicoff, A., Braun-Inglis, C., Okado, I., & Bakos, A. (2022). Through the Lens of Patient Partners: Challenges in Accrual of Older Adults to NCI Clinical Trials. Journal of the National Cancer Institute. Monographs, 2022(60), 125–134. 10.1093/jncimonographs/lgac022 36519817
Brody, A. A., Convery, K. A., Kline, D. M., Fink, R. M., & Fischer, S. M. (2022). Transitioning to Remote Recruitment and Intervention: A Tale of Two Palliative Care Research Studies Enrolling Underserved Populations During COVID-19. Journal of Pain and Symptom Management, 63(1), 151–159. 10.1016/j.jpainsymman.2021.06.017 34161811
Calderón, J. L., Baker, R. S., Fabrega, H., Conde, J. G., Hays, R. D., Fleming, E., & Norris, K. (2006). An Ethno-medical Perspective on Research Participation: A Qualitative Pilot Study. Medscape General Medicine, 8(2), 23.
Caston, N. E., Lalor, F., Wall, J., Sussell, J., Patel, S., Williams, C. P., Azuero, A., Arend, R., Liang, M. I., & Rocque, G. B. (2022). Ineligible, Unaware, or Uninterested? Associations Between Underrepresented Patient Populations and Retention in the Pathway to Cancer Clinical Trial Enrollment. JCO Oncology Practice, 18(11), e1854–e1865. 10.1200/OP.22.00359 36178922
Chino, F., Peppercorn, J. M., Rushing, C., Kamal, A. H., Altomare, I., Samsa, G., & Zafar, S. Y. (2017). Out-of-Pocket Costs, Financial Distress, and Underinsurance in Cancer Care. JAMA Oncology, 3(11), 1582–1584. 10.1001/jamaoncol.2017.2148 28796862
Chino, F., Peppercorn, J. M., Rushing, C., Nicolla, J., Kamal, A. H., Altomare, I., Samsa, G., & Zafar, S. Y. (2018). Going for Broke: A Longitudinal Study of Patient-Reported Financial Sacrifice in Cancer Care. Journal of Oncology Practice. 10.1200/JOP.18.00112
Chino, F., & Zafar, S. Y. (2019). Financial Toxicity and Equitable Access to Clinical Trials. American Society of Clinical Oncology Educational Book, 39, 11–18. 10.1200/EDBK_100019 31099681
Cook, E. D., Arnold, K. B., Hermos, J. A., McCaskill-Stevens, W., Moody-Thomas, S., Probstfield, J. L., Hamilton, S. J., Campbell, R. D., Anderson, K. B., & Minasian, L. M. (2010). Impact of supplemental site grants to increase African American accrual for the Selenium and Vitamin E Cancer Prevention Trial. Clinical Trials (London, England), 7(1), 90–99. 10.1177/1740774509357227 20156960
Coon, E. R., Schroeder, A. R., Lion, K. C., & Ray, K. N. (2022). Disparities by Ethnicity in Enrollment of a Clinical Trial. Pediatrics, 149(2), e2021052595. 10.1542/peds.2021-052595 35043194
de Souza, J. A., Yap, B. J., Wroblewski, K., Blinder, V., Araújo, F. S., Hlubocky, F. J., Nicholas, L. H., O’Connor, J. M., Brockstein, B., Ratain, M. J., Daugherty, C. K., & Cella, D. (2017). Measuring financial toxicity as a clinically relevant patient-reported outcome: The validation of the COmprehensive Score for financial Toxicity (COST). Cancer, 123(3), 476–484. 10.1002/cncr.30369 27716900
Duma, N., Aguilera, J. V., Paludo, J., Haddox, C. L., Velez, M. G., Wang, Y., Leventakos, K., Hubbard, J. M., Mansfield, A. S., Go, R. S., & Adjei, A. A. (2017). Representation of Minorities and Women in Oncology Clinical Trials: Review of the Past 14 Years. Journal of Oncology Practice. 10.1200/JOP.2017.025288
Ejem, D. B., Wechsler, S., Gallups, S., Khalidi, S., Coffee-Dunning, J., Montgomery, A. P., Stevens, C. J., Keene, K., Rocque, G. B., Chamberlin, M., Hegel, M. T., Azuero, A., Pisu, M., Ellis, D., Ingram, S. A., Lawhon, V. M., Gilbert, T., Morrissette, K., Morency, J., … Lyons, K. D. (2023). Enhancing Efficiency and Reach Using Facebook to Recruit Breast Cancer Survivors for a Telephone-Based Supportive Care Randomized Trial During the COVID-19 Pandemic. JCO Oncology Practice, 19(11), 1020–1030. 10.1200/OP.23.00117
Ellis, S. D., Carpenter, W. R., Minasian, L. M., & Weiner, B. J. (2012). Effect of state-mandated insurance coverage on accrual to community cancer clinical trials. Contemporary Clinical Trials, 33(5), 933–941. 10.1016/j.cct.2012.06.001 22683991
Gafford, J. A., Gurley-Calvez, T., Krebill, H., Lai, S. M., Christiadi, & Doolittle, G. C. (2017). Expanding Local Cancer Clinical Trial Options: Analysis of the Economic Impact of the Midwest Cancer Alliance in Kansas. Academic Medicine, 92(9), 1274–1279. 10.1097/ACM.0000000000001612 28253204
Gerber, D. E., Lakoduk, A. M., Priddy, L. L., Yan, J., & Xie, X.-J. (2015). Temporal Trends and Predictors for Cancer Clinical Trial Availability for Medically Underserved Populations. The Oncologist, 20(6), 674–682. 10.1634/theoncologist.2015-0083 26018661
Gerber, D. E., Tiro, J. A., McNeill, L. H., Williams, E. L., Zhu, H., Lee, S. J. C., Leavey, P. J., Sadeghi, N., Kapinos, K. A., Dornsife, D. L., Nguyen, V., Wileyto, E. P., & Guerra, C. E. (2022). Enhancing access to and diversity in cancer clinical trials through a financial reimbursement program: Protocol to evaluate a novel program. Contemporary Clinical Trials, 121, 106922. 10.1016/j.cct.2022.106922 36096281
Gharzai, L. A., & Jagsi, R. (2023). Incorporating financial toxicity considerations into clinical trial design to facilitate patient-centered decision-making in oncology. Cancer, 129(8), 1143–1148. 10.1002/cncr.34677 36775839
Giuliano, A. R., Mokuau, N., Hughes, C., Tortolero-Luna, G., Risendal, B., Ho, R. C. S., Prewitt, T. E., & Mccaskill-Stevens, W. J. (2000). Participation of Minorities in Cancer Research: The Influence of Structural, Cultural, and Linguistic Factors. Annals of Epidemiology, 10(8, Supplement 1), S22–S34. 10.1016/s1047-2797(00)00195-2 11189089
Guerra, C. E., Fleury, M. E., Byatt, L. P., Lian, T., & Pierce, L. (2022). Strategies to Advance Equity in Cancer Clinical Trials. American Society of Clinical Oncology Educational Book. American Society of Clinical Oncology. Annual Meeting, 42, 1–11. 10.1200/EDBK_350565
Hamel, L. M., Penner, L. A., Albrecht, T. L., Heath, E., Gwede, C. K., & Eggly, S. (2016). Barriers to Clinical Trial Enrollment in Racial and Ethnic Minority Patients With Cancer. Cancer Control: Journal of the Moffitt Cancer Center, 23(4), 327– 337. 10.1177/107327481602300404 27842322
Hardie, G., Liu, R., Darden, J., & Gold, W. M. (2010). Ethnic differences in methacholine responsiveness and word descriptors in African Americans, Hispanic-Mexican Americans, Asian-Pacific Islanders, and Whites with mild asthma. The Journal of Asthma: Official Journal of the Association for the Care of Asthma, 47(4), 388–396. 10.3109/02770903.2010.481341 20528591
Holmes, D. R., Major, J., Lyonga, D. E., Alleyne, R. S., & Clayton, S. M. (2012). Increasing minority patient participation in cancer clinical trials using oncology nurse navigation. American Journal of Surgery, 203(4), 415–422. 10.1016/j.amjsurg.2011.02.005 21996347
Huey, R. W., George, G. C., Phillips, P., White, R., Fu, S., Janku, F., Karp, D. D., Naing, A., Piha-Paul, S., Subbiah, V., Tsimberidou, A. M., Pant, S., Yap, T. A., Rodon, J., Meric-Bernstam, F., Shih, Y.-C. T., & Hong, D. S. (2021). Patient-Reported Out-of-Pocket Costs and Financial Toxicity During Early-Phase Oncology Clinical Trials. The Oncologist, 26(7), 588–596. 10.1002/onco.13767 33783054
Kaasa, S., Bjordal, K., Aaronson, N., Moum, T., Wist, E., Hagen, S., & Kvikstad, A. (1995). The EORTC core quality of life questionnaire (QLQ-C30): validity and reliability when analysed with patients treated with palliative radiotherapy. European journal of cancer (Oxford, England: 1990), 31A(13–14), 2260–2263. 10.1016/0959-8049(95)00296-0 8652253
Kehl, K. L., Fullmer, C. P., Fu, S., George, G. C., Hess, K. R., Janku, F., Karp, D. D., Kato, S., Kizer, C. K., Kurzrock, R., Naing, A., Pant, S., Piha-Paul, S. A., Subbiah, V., Tsimberidou, A. M., & Hong, D. S. (2017). Insurance Clearance for Early-Phase Oncology Clinical Trials Following the Affordable Care Act. Clinical Cancer Research: An Official Journal of the American Association for Cancer Research, 23(15), 4155–4162. 10.1158/1078-0432.CCR-16-3027 28729355
Keilson, J. M., Lindsey, S., Bachini, M., Medin, C. R., Berk, A., Cornew, S., & Maithel, S. K. (2022). Patient reported outcomes: Financial toxicity is a barrier to clinical trials and personalized therapy in cholangiocarcinoma. Journal of Surgical Oncology, 126(6), 1003–1010. 10.1002/jso.27012 35839090
Kilgore, M. L., & Goldman, D. P. (2008). Drug costs and out-of-pocket spending in cancer clinical trials. Contemporary Clinical Trials, 29(1), 1–8. 10.1016/j.cct.2007.04.004 17544339
King, A. C., Cao, D., Southard, C. C., & Matthews, A. (2011). Racial differences in eligibility and enrollment in a smoking cessation clinical trial. Health Psychology: Official Journal of the Division of Health Psychology, American Psychological Association, 30(1), 40–48. 10.1037/a0021649 21299293
Kunos, C. A., & Abdallah, R. (2020). Financial Toxicity Encountered in Therapeutic Radiopharmaceutical Clinical Development for Ovarian Cancer. Pharmaceuticals (Basel, Switzerland), 13(8), 181. 10.3390/ph13080181 32764223
Langford, A. T., Resnicow, K., Dimond, E. P., Denicoff, A. M., Germain, D. St., McCaskill-Stevens, W., Enos, R. A., Carrigan, A., Wilkinson, K., & Go, R. S. (2014). Racial/ethnic differences in clinical trial enrollment, refusal rates, ineligibility, and reasons for decline among patients at sites in the National Cancer Institute’s Community Cancer Centers Program. Cancer, 120(6), 877–884. 10.1002/cncr.28483 24327389
Largent, E. A., Heffernan, K. G., Joffe, S., & Lynch, H. F. (2020). Paying Clinical Trial Participants: Legal Risks and Mitigation Strategies. Journal of Clinical Oncology, 38(6), 532–537. 10.1200/JCO.19.00250 31199697
Largent, E. A., & Lynch, H. F. (2018). Addressing Financial Barriers to Enrollment in Clinical Trials. JAMA Oncology, 4(7), 913–914. 10.1001/jamaoncol.2018.0492 29710211
Lee, A., Shah, K., & Chino, F. (2020). Assessment of Parking Fees at National Cancer Institute–Designated Cancer Treatment Centers. JAMA Oncology, 6(8), 1295. 10.1001/jamaoncol.2020.1475 32672809
Mackay, C. B., Gurley-Calvez, T., Erickson, K. D., & Jensen, R. A. (2016). Clinical trial insurance coverage for cancer patients under the Affordable Care Act. Contemporary Clinical Trials Communications, 2, 69–74. 10.1016/j.conctc.2015.12.002 29736447
MacLennan, D. L., Plahovinsak, J. L., MacLennan, R. J., & Jones, C. T. (2023). Clinical Trial Site Perspectives and Practices on Study Participant Diversity and Inclusion. Clinical Pharmacology & Therapeutics, 113(3), 670–679. 10.1002/cpt.2817 36495475
Manne, S., Kashy, D., Albrecht, T., Wong, Y.-N., Lederman Flamm, A., Benson, A. B., Miller, S. M., Fleisher, L., Buzaglo, J., Roach, N., Katz, M., Ross, E., Collins, M., Poole, D., Raivitch, S., Miller, D. M., Kinzy, T. G., Liu, T., & Meropol, N. J. (2015). Attitudinal barriers to participation in oncology clinical trials: Factor analysis and correlates of barriers. European Journal of Cancer Care, 24(1), 28–38. 10.1111/ecc.12180 24467411
Martin, P. J., Davenport-Ennis, N., Petrelli, N. J., Stewart, F. M., Appelbaum, F. R., & Benson, A. (2014). Responsibility for Costs Associated With Clinical Trials. Journal of Clinical Oncology, 32(30), 3357–3359. 10.1200/JCO.2014.57.1422 25225433
Masoli, J. A. H., Down, K., Nestor, G., Hudson, S., O’Brien, J. T., Williamson, J. D., Young, C. A., Carroll, C., & NIHR Remote Trial Delivery Working Group. (2021). A report from the NIHR UK working group on remote trial delivery for the COVID-19 pandemic and beyond. Trials, 22(1), 911. 10.1186/s13063-021-05880-8 34895305
McElfish, P. A., Long, C. R., Selig, J. P., Rowland, B., Purvis, R. S., James, L., Holland, A., Felix, H. C., & Narcisse, M. (2018). Health Research Participation, Opportunity, and Willingness Among Minority and Rural Communities of Arkansas. Clinical and Translational Science, 11(5), 487–497. 10.1111/cts.12561 29772113
Medina, S. P., Zhang, S., Nieves, E., Dornsife, D. L., Johnson, R., Spicer, D., & Borno, H. T. (2023). Experiences of a Multiethnic Cohort of Patients Enrolled in a Financial Reimbursement Program for Cancer Clinical Trials. JCO Oncology Practice, 19(5), e801–e810. 10.1200/OP.22.00429 36800640
Mupfudze, T. G., Preussler, J. M., Sees, J. A., SanCartier, M., Arnold, S. D., & Devine, S. (2021). A Qualitative Analysis of State Medicaid Coverage Benefits for Allogeneic Hematopoietic Cell Transplantation (alloHCT) for Patients with Sickle Cell Disease (SCD). Transplantation and Cellular Therapy, 27(4), 345–351. 10.1016/j.jtct.2021.01.022 33836889
Murphy, A. L., Turner, J. P., Rajda, M., Allen, K. G., Pinter, K., & Gardner, D. M. (2023). Effectiveness and cost analysis of methods used to recruit older adult sedative users to a deprescribing randomized controlled trial during the COVID-19 pandemic. Exploratory Research in Clinical and Social Pharmacy, 9, 100214. 10.1016/j.rcsop.2022.100214 36540425
National Academies of Sciences, Engineering, and Medicine. 2022. Improving Representation in Clinical Trials and Research: Building Research Equity for Women and Underrepresented Groups. Washington, DC: The National Academies Press. 10.17226/26479.
Nipp, R. D., Hong, K., & Paskett, E. D. (2019). Overcoming Barriers to Clinical Trial Enrollment. American Society of Clinical Oncology Educational Book, 39, 105–114. 10.1200/EDBK_243729
Nipp, R. D., Lee, H., Gorton, E., Lichtenstein, M., Kuchukhidze, S., Park, E., Chabner, B. A., & Moy, B. (2019). Addressing the Financial Burden of Cancer Clinical Trial Participation: Longitudinal Effects of an Equity Intervention. The Oncologist, 24(8), 1048–1055. 10.1634/theoncologist.2019-0146 30988039
Nipp, R. D., Lee, H., Powell, E., Birrer, N. E., Poles, E., Finkelstein, D., Winkfield, K., Percac-Lima, S., Chabner, B., & Moy, B. (2016). Financial Burden of Cancer Clinical Trial Participation and the Impact of a Cancer Care Equity Program. The Oncologist, 21(4), 467–474. 10.1634/theoncologist.2015-0481 26975867
Nipp, R. D., Powell, E., Chabner, B., & Moy, B. (2015). Recognizing the Financial Burden of Cancer Patients in Clinical Trials. The Oncologist, 20(6), 572–575. 10.1634/theoncologist.2015-0068 25986245
Olivier, T., Haslam, A., & Prasad, V. (2023). Is financial toxicity captured in quality of life assessments in oncology randomized clinical trials? Journal of Cancer Policy, 36, 100423. 10.1016/j.jcpo.2023.100423 37075841
Paidipati, C. P., Foxwell, A. M., Mooney-Doyle, K., Tiller, D., Pinto-Martin, J., & Ulrich, C. M. (2023). Caregiver Perspectives on the Benefits, Burdens, and Moral Distress of Participation in Cancer Clinical Trials. Journal of Family Nursing, 29(1), 89–98. 10.1177/10748407221098187 35611586
Perni, S., Azoba, C., Gorton, E., Park, E. R., Chabner, B. A., Moy, B., & Nipp, R. D. (2022). Financial Toxicity, Symptom Burden, Illness Perceptions, and Communication Confidence in Cancer Clinical Trial Participants. JCO Oncology Practice, 18(9), e1427–e1437. 10.1200/OP.21.00697 35666957
Perni, S., Moy, B., & Nipp, R. D. (2021). Disparities in phase 1 cancer clinical trial enrollment. Cancer, 127(23), 4464– 4469. 10.1002/cncr.33853 34379799
Pisu, M., Azuero, A., Meneses, K., Burkhardt, J., & McNees, P. (2011). Out of pocket cost comparison between Caucasian and minority breast cancer survivors in the Breast Cancer Education Intervention (BCEI). Breast Cancer Research and Treatment, 127(2), 521–529. 10.1007/s10549-010-1225-0 20976542
Popkin, R., Taylor-Zapata, P., & Bianchi, D. W. (2022). Physician Bias and Clinical Trial Participation in Underrepresented Populations. Pediatrics, 149(2), e2021054150. 10.1542/peds.2021-054150 35043204
Prasad, R. N., Royce, T. J., Chino, F., Jagsi, R., & Palmer, J. D. (2022). Financial Toxicity as an End Point in Prospective Clinical Trials Involving Radiation Therapy. Advances in Radiation Oncology, 7(6), 100970. 10.1016/j.adro.2022.100970 35620674
Raciborski, R. A., Hamerling-Potts, K. K., Mitchell, E. L., Sullivan, S. R., Kapil-Pair, N., Landes, S. J., Jager-Hyman, S., & Goodman, M. (2023). Cost comparison of in-person and telehealth modalities for a suicide safety planning group intervention: Interim results from the “Project Life Force” randomized clinical trial. Frontiers in Psychiatry, 14, 1215247. 10.3389/fpsyt.2023.1215247 37915795
Reoma, L. B., & Karp, B. I. (2022). The Human Cost: Patient Contribution to Clinical Trials in Neurology. Neurotherapeutics: The Journal of the American Society for Experimental NeuroTherapeutics, 19(5), 1503–1506. 10.1007/s13311-022-01292-x 36083396
Riaz, I. B., Islam, M., Ikram, W., Naqvi, S. A. A., Maqsood, H., Saleem, Y., Riaz, A., Ravi, P., Wang, Z., Hussain, S. A., Warner, J. L., Odedina, F. T., Duma, N., Singh, P., Kehl, K. L., Kamran, S. C., Murad, M. H., Landman, A., Van Allen, E., & Bryce, A. H. (2023). Disparities in the Inclusion of Racial and Ethnic Minority Groups and Older Adults in Prostate Cancer Clinical Trials: A Meta-analysis. JAMA Oncology, 9(2), 180–187. 10.1001/jamaoncol.2022.5511 36416812
Rocque, G. B., Andrews, C., Lawhon, V. M., Frazier, R., Ingram, S. A., Smith, M. L., Wagner, L. I., Zubkoff, L., Tung, N., Wallner, L. P., & Wolff, A. C. (2023). Oncologist-Reported Barriers and Facilitators to Enrolling Patients in Optimization Trials That Test Less Intense Cancer Treatment. JCO Oncology Practice, 19(2), e263–e273. 10.1200/OP.22.00472 36473142
Sehrawat, O., Noseworthy, P. A., Siontis, K. C., Haddad, T. C., Halamka, J. D., & Liu, H. (2023). Data-Driven and Technology-Enabled Trial Innovations Toward Decentralization of Clinical Trials: Opportunities and Considerations. Mayo Clinic Proceedings, 98(9), 1404–1421. 10.1016/j.mayocp.2023.02.003 37661149
Sidana, S., Allmer, C., Larson, M. C., Dueck, A., Yost, K., Warsame, R., Thanarajasingam, G., Cerhan, J. R., Paludo, J., Rajkumar, S. V., Habermann, T. M., Nowakowski, G. S., Lin, Y., Gertz, M. A., Witzig, T., Dispenzieri, A., Gonsalves, W. I., Ansell, S. M., Thompson, C. A., & Kumar, S. K. (2022). Patient Experience in Clinical Trials: Quality of Life, Financial Burden, and Perception of Care in Patients With Multiple Myeloma or Lymphoma Enrolled on Clinical Trials Compared With Standard Care. JCO Oncology Practice, 18(8), e1320–e1333. 10.1200/OP.21.00789 35580285
Tan, A. C., Ashley, D. M., & Khasraw, M. (2020). Adapting to a Pandemic—Conducting Oncology Trials during the SARS-CoV-2 Pandemic. Clinical Cancer Research: An Official Journal of the American Association for Cancer Research, 26(13), 3100–3103. 10.1158/1078-0432.CCR-20-1364 32312892
Thetford, K., Gillespie, T. W., Kim, Y., Hansen, B., & Scarinci, I. C. (n.d.). Willingness of Latinx and African Americans to Participate in Nontherapeutic Trials: It Depends on Who Runs the Research. Ethnicity & Disease, 31(2), 263–272. https://pubmed.ncbi.nlm.nih.gov/33883867/
Unger, J. M., & Fleury, M. E. (2019). Reimbursing Patients for Participation in Cancer Clinical Trials. JAMA Oncology, 5(7), 932–934. 10.1001/jamaoncol.2019.0141 31169875
Unger, J. M., Gralow, J. R., Albain, K. S., Ramsey, S. D., & Hershman, D. L. (2016). Patient Income Level and Cancer Clinical Trial Participation in a Prospective Survey Study. JAMA Oncology, 2(1), 137–139. 10.1001/jamaoncol.2015.3924 26468994
Unger, J. M., Hershman, D. L., Albain, K. S., Moinpour, C. M., Petersen, J. A., Burg, K., & Crowley, J. J. (2013). Patient Income Level and Cancer Clinical Trial Participation. Journal of Clinical Oncology, 31(5), 536–542. 10.1200/JCO.2012.45.4553 23295802
Unger, J. M., Xiao, H., Vaidya, R., LeBlanc, M., & Hershman, D. L. (2023). Medicaid Expansion of the Patient Protection and Affordable Care Act and Participation of Patients With Medicaid in Cancer Clinical Trials. JAMA Oncology, 9(10), 1371–1379. 10.1001/jamaoncol.2023.2800 37590003
Virani, S., Burke, L., Remick, S. C., & Abraham, J. (2011). Barriers to Recruitment of Rural Patients in Cancer Clinical Trials. Journal of Oncology Practice, 7(3), 172–177. 10.1200/JOP.2010.000158 21886499
Walter, J. K., Burke, J. F., & Davis, M. M. (2013). Research Participation by Low-Income and Racial/Ethnic Minority Groups: How Payment May Change the Balance. Clinical and Translational Science, 6(5), 363–371. 10.1111/cts.12084 24127923
Ward, E., Jemal, A., Cokkinides, V., Singh, G. K., Cardinez, C., Ghafoor, A., & Thun, M. (2004). Cancer disparities by race/ethnicity and socioeconomic status. CA: A Cancer Journal for Clinicians, 54(2), 78–93. 10.3322/canjclin.54.2.78 15061598
Williams, C. P., Geiger, A. M., Norton, W. E., de Moor, J. S., & Everson, N. S. (2023). Influence of Cost-Related Considerations on Clinical Trial Participation: Results from the 2020 Health Information National Trends Survey (HINTS). Journal of General Internal Medicine, 38(5), 1200–1206. 10.1007/s11606-022-07801-0 36451016
Williams, C. P., Senft Everson, N., Shelburne, N., & Norton, W. E. (2021). Demographic and Health Behavior Factors Associated With Clinical Trial Invitation and Participation in the United States. JAMA Network Open, 4(9), e2127792. 10.1001/jamanetworkopen.2021.27792 34586365
Williams, M. J., Okai, A. F., Cross, A. H., Monson, N. L., Vartanian, T., Thrower, B. W., Reder, A. T., English, J. B., Wu, G. F., Bernitsas, E., Yap, S., Ndrio, J., Pei, J., Mowry, E. M., Magrini, F., Acosta, J., & Amezcua, L. (2023). Demographics and baseline disease characteristics of Black and Hispanic patients with multiple sclerosis in the open-label, single-arm, multicenter, phase IV CHIMES trial. Multiple Sclerosis and Related Disorders, 76, 104794. 10.1016/j.msard.2023.104794 37356256
Winkfield, K. M. (2020). Improving access to cancer clinical trials by reducing the financial burden. Cancer, 126(1), 14– 16. 10.1002/cncr.32523 31581309
Winkfield, K. M., Phillips, J. K., Joffe, S., Halpern, M. T., Wollins, D. S., & Moy, B. (2018). Addressing Financial Barriers to Patient Participation in Clinical Trials: ASCO Policy Statement. Journal of Clinical Oncology, 36(33), 3331–3339. 10.1200/JCO.18.01132
Wong, Y.-N., Schluchter, M. D., Albrecht, T. L., Benson, A. B., Buzaglo, J., Collins, M., Flamm, A. L., Fleisher, L., Katz, M., Kinzy, T. G., Liu, T. M., Manne, S., Margevicius, S., Miller, D. M., Miller, S. M., Poole, D., Raivitch, S., Roach, N., Ross, E., & Meropol, N. J. (2016). Financial Concerns About Participation in Clinical Trials Among Patients With Cancer. Journal of Clinical Oncology: Official Journal of the American Society of Clinical Oncology, 34(5), 479–487. 10.1200/JCO.2015.63.2463 26700120