# Acknowledgments

The authors wish to thank Sue Felt-Lisk, Chris Palo, Donovan Griffin, and Barbara Collette at Mathematica for their contributions to this work. We would also like to acknowledge the following individuals:

- Allison Kolbe, PhD, ASPE
- Trinidad Beleche, PhD, ASPE
- Deborah Porterfield, MD, MPH, ASPE
- Jessica White, MPP, ASPE
- Kathleen Miller, PhD MS, ASPE
- Contract Officer’s Representative, Marsha Clarke, PhD, ASPE
- Hope King, PhD, MSPH, Centers for Disease Control and Prevention
- Christine Lee, Pharm. D, PhD, Food and Drug Administration
- Winifred (Ann) Meeker-O’Connell, Food and Drug Administration
- Richard P. Moser, National Cancer Institute, National Institutes of Health
- Kelly Blake, SCD, National Cancer Institute, National Institutes of Health
- Courtney P. Williams, DrPH, University of Alabama at Birmingham