# Executive Summary

## Background

Under the Lessons Learned from the COVID-19 Pandemic contract funded by the Office of the Assistant Secretary for Planning and Evaluation, Mathematica is identifying the impact of COVID-19 on the costs to patients associated with clinical trial participation and particularly how the use of novel strategies such as remote technologies affected costs to patients. One important component of this work is to conduct an environmental scan meant to provide context for survey development and help us identify gaps in the literature related to costs to patients participating in clinical trials, both before and during the COVID-19 pandemic. In particular, the environmental scan addressed the following topics:

1. The types of direct and indirect costs to patients associated with clinical trial participation, including any estimates of such costs in the literature.
2. Recognizing that payers are required to cover “routine care costs,” the types of costs that are not considered “routine care” or may not be covered by payers.
3. Financial and nonfinancial barriers on participation in clinical trials by sociodemographic groups, with an emphasis on historically underrepresented groups.
4. The effect of COVID-19 on costs to patients, including cost implications of clinical trial innovations widely implemented during COVID-19 (for example, remote monitoring and decentralized trials) and efforts to increase diversity of trial participants by reducing barriers to participation.

## Methods

We searched three academic databases to identify peer-reviewed literature published from 2010 to 2023 using key search terms related to the topics above. We also searched for grey literature on clinical trial, cancer research, and patient advocacy group websites, Google, and GoogleScholar. After completing the initial article review, we conducted a backward and forward snowball search using the articles we identified in the first round of the formal literature search to supplement our findings.

We identified 3,192 articles across the four search topics. After a title review for relevance, we removed 3,076 articles that did not focus on the topics of clinical trials costs to patients or barriers to clinical trial participation. We added an additional 88 relevant articles or sources from the grey literature to the abstract review for a total of 204 articles. Based on an abstract review of the 204 articles, we removed 161 articles that did not have a direct discussion of costs to patients or barriers to clinical trial participation, leaving 44 articles remaining from the initial review. We then conducted forward and backward snowball searches to add another 40 full text articles, yielding a total of 84 full text articles or resources included in the final environmental scan.

## Key Takeaways

In Exhibit ES.1, we list the key findings by topic area, as well as the gaps we identified in the literature.

Exhibit ES.1 Key findings and gaps from the literature search

Topic | Summary of literature and key findings | Gaps in literature
Types and estimates of direct and indirect costs to patients in clinical trials | Summary: A limited number of studies quantified direct or indirect costs to patients in clinical trials, with most studies focusing on estimates of travel costs and reimbursement.; - Direct costs included copays, coinsurance, deductibles, medication costs, and general out-of-pocket spending, with mixed evidence on whether patients enrolled in clinical trials have more out-of-pocket medical costs.; - Travel costs were the most commonly reported indirect cost and ranged from $200 to $1,000 per month before the COVID-19 pandemic.; - Other indirect costs included in the literature were dependent care, meals, and missed work or lost wages.; - Researchers recommend collecting information about patient-reported financial toxicity during trials, but uptake of the recommendation is slow. | - Few studies directly compared the out-of-pocket direct costs for patients enrolled and not enrolled in clinical trials; - Most studies focused on direct and indirect costs to patients were among patients with cancer.; - Some studies reported financial toxicity as a composite measure rather than direct or indirect costs, but this metric is captured infrequently in clinical trials.; - No papers quantified the impact of COVID-19-related modifications (remote monitoring, decentralized trials, and so on) on direct or indirect costs.; - Lost wages might represent a significant cost to patients, but few studies quantified them.
Impact of policies requiring that payers cover “routine care costs” during clinical trials and costs covered by payers as “routine care” | Summary: Information on what is covered under routine care is varied and limited. Variation in the implementation of these policies contributes to gaps in policy coverage.; - Coverage for routine care varied by payer and state over the last 20 years with Medicaid being the last to adopt coverage in all states.; - Payers can still deny coverage for trials at out-of-network sites.; - There was some evidence that newly adopted state-level policies requiring insurers to cover “patient care costs” in clinical trials had no statistical impact on clinical trial participation rates.; - Patients still experience the financial burden of direct costs such as coinsurance, which routine care policies do not address. | - There is limited information in the literature on what costs payers consider routine care.; - There are few studies on the impact of routine care policies and those that do exist show mixed effects on trial participation.
Impact of financial and nonfinancial barriers on clinical trial participation among historically underrepresented groups | Summary: Financial and nonfinancial barriers for some underrepresented groups have been addressed in the literature, with lower socioeconomic status identified as the one of the largest overarching barriers to trial participation.; - Socioeconomic factors (including education level, employment status, income level, and insurance status) contribute to observed disparities and present a significant barrier to trial participation, especially for Black and Hispanic patients, patients older than age 65, and rural patients.; - Reimbursement for costs associated with clinical trials such as travel could address disparities in participation.; - Nonfinancial barriers include patient awareness, encouragement from providers to participate, regional availability, distrust of the health system, logistical barriers, and ineligibility, including because of age and health status. | - There was limited information on the impact of COVID-19 on barriers to clinical trial enrollment.; - There was also limited information on the difference in costs of participation by underrepresented group.; - The literature generally focused on barriers for racial and ethnic minorities, rural populations and elderly populations but there was comparatively little evidence on barriers for other underrepresented populations such as pregnant and lactating people, LGBTQIA+ populations, children, or people with disabilities.
Effects of COVID-19 and clinical trial innovations like remote monitoring on costs to patients, diversity of trial participants, and barriers to trial participation | Summary: No studies focused on the effects of COVID-19 on costs to patients, but some studies suggested there were benefits of clinical trial innovations on reducing barriers to trial participation.; - Some patients reported benefits from remote study visits such as reduced time commitment and travel costs (qualitative findings only).; - Remote study visits presented some technological challenges for patients and could disadvantage older or low-income patients without reliable internet access. | - There were no cost estimates on the impact of remote study visits or other decentralized elements in trials on indirect costs such as travel.; - There was limited information on the effects of the following innovations on costs, diversity, and barriers to participation: cost reimbursement, home visits and relaxed follow-up timeframes.

Based on these findings, we identified areas for future work to address some key gaps in the literature, including the following:

- Estimates of direct and indirect costs to patients, including out-of-pocket medical spending, travel costs, and lost work productivity, in by trial phase and type.
- Patient’s experience with insurance coverage during the clinical trial, including instances of denied coverage for clinical trial monitoring tests or clinical trial sites that were out-of-network or types of care that were not considered ‘routine care costs’ during the trial.
- The impact of eligibility barriers on clinical trial participation and approaches to adapt trial inclusion and exclusion criteria to reduce eligibility barriers for underrepresented groups.

Patient’s experience and comfort-level with remote monitoring, telehealth, or other remote technology.