# VI Discussion and Conclusions

To inform our understanding of the costs and barriers that patients might face when participating in a clinical trial, as well as the impact of COVID-19 on those costs and barriers, we gathered related literature for this environmental scan. Our findings are listed in Exhibit VI.I. One key finding was that Black and Hispanic patients, patients over age 65, and rural patients have lower clinical trial participation, which might be driven in part by lower socioeconomic status. Below we summarize the literature that suggests strategies to address barriers to clinical trial enrollment.

Some strategies in the literature that may help address some key barriers to clinical trial enrollment include nurse navigators and decentralized approaches to trials. The use of decentralized or remote trials may help to reduce barriers to enrollment like travel and time commitment (Raciborski et al. 2023, Sehrawat et al. 2023). A study at the University of Southern California found that nurse navigators increased the recruitment rate of Black patients with breast cancer into clinical trials and enrolled 86 percent of eligible patients into clinical trials (Holmes et al. 2012). Guerra et al. (2022) wrote a commentary article on approaches to advance equity in cancer clinical trials. Some of these approaches include the use of patient or nurse navigators to increase understanding of trial benefits and provide decision-making support. The authors also stressed the need for financial and social needs assistance to cover out-of-pocket trial expenses like transportation. Duke Cancer Institute’s Health Disparities & Equity Program implemented a patient navigator program to help patients through both routine cancer care and a Community Health Ambassador Program to promote awareness about clinical trial opportunities (Barrett et al. 2016).

Several studies argued that financial support or reimbursement during trials may help to overcome financial barriers and improve representation (Unger and Fleury 2019, Largent and Lynch 2018, Winkfield 2020). In a nationally representative survey of US adults, Hispanic respondents requested higher amounts of compensation to participate in clinical research than non-Hispanic White or Black respondents (Walter et al. 2013). The authors found that a payment of approximately $350 would yield proportional representation, or willingness to participate, in clinical research. A cancer prevention trial increased the proportion of Black participants from 27.2 percent to 31.5 percent, and the number of total recruits for the trial at sites that received Minority Recruitment Enhancement Grants (MREGs) (Cook et al. 2010). The MREGs were $50,000 grants to trial sites that funded salary support for a minority outreach coordinator, reimbursement for parking and gas for participants, and other recruitment materials. A financial reimbursement program focused on increasing the number and diversity of participants at a cancer clinical trial site in Dallas, Texas (Gerber et al. 2022). The reimbursement program, funded by Lazarex Cancer Foundation, provided funding to patients for non-clinical costs associated with trial participant, including travel and lodging, for patients with household incomes up to 700 percent of the Federal poverty rate. Financial support will be up to $1,500 per month for patients at 400 percent of the Federal poverty rate, up to $1,125 per month for patients between 401 and 550 percent of the Federal poverty rate, and up to $750 per month for patients between 551 and 700 percent of the Federal poverty rate. Another financial reimbursement program funded by the Lazarex Cancer Foundation at two cancer centers in California found that implementing the reimbursement program was feasible at a comprehensive cancer center; however, there was no evidence of improved clinical trial enrollment rates for those receiving reimbursement. The biggest barrier to clinical trial enrollment reported in the study was ineligibility due to screening procedures (Borno et al. 2022b). Finally, an open-label, phase IV trial among Black and Hispanic patients with multiple sclerosis was specifically designed to promote retention and decrease burden by providing reimbursement for childcare, transportation, earnings loss, and travel and by providing more flexibility in visit windows (Williams et al. 2023).

In Exhibit IV.1, we summarize the topic areas for the environmental scan and the key findings for each topic. We also detail the areas where there are gaps in the literature. Based on these findings, topics for future work could include the following (additional detail offered in the right column of Exhibit IV.1):

- Estimates of direct and indirect costs to patients, including out-of-pocket medical spending, travel costs, and lost work productivity, in by trial phase and type.
- Patient’s experience with insurance coverage during the clinical trial, including instances of denied coverage for clinical trial monitoring tests or clinical trial sites that were out-of-network or types of care that were not considered ‘routine care costs’ during the trial.
- The impact of eligibility barriers on clinical trial participation and approaches to adapt trial inclusion and exclusion criteria to reduce eligibility barriers for underrepresented groups.
- Patient’s experience and comfort-level with remote monitoring, telehealth, or other remote technology.

Exhibit IV.1 Environmental scan findings by topic area

Topic | Key Findings | Gaps in Literature | Questions for Further Exploration
Types and estimates of direct and indirect costs to patients in clinical trials | - Direct costs include coinsurance, copays, deductibles, medication costs, and general out-of-pocket spending, with mixed evidence on whether patients enrolled in clinical trials have more out-of-pocket medical costs.; - Travel costs ranged from $200 to $1,000 per month prior to the COVID-19 pandemic.; - Other indirect costs include travel meals, dependent care, missed work or lost wages, and companion costs.; - Research supports collecting patient-reported financial toxicity, but uptake in clinical trials is slow. | - Few studies quantified differences in direct costs for patients enrolled and not enrolled in clinical trials.; - Most studies on direct and indirect costs focused on patients with cancer.; - Indirect costs in the literature focused mainly on travel costs.^4^; - No papers quantified the impact of COVID-19-related modifications (remote monitoring, decentralized trials, and so on) on direct or indirect costs.; - Lost wages may represent a significant cost to patients, but few studies quantified them. | - What are the out-of-pocket medical costs related to clinical trial participation (coinsurance, copays, deductibles, etc....)?; - What are the out-of-pocket non-medical costs related to clinical trial participation (transportation, lodging, childcare, etc....)?; - How does clinical trial participation impact lost work productivity?
Impact of policies requiring that payers cover “routine care costs” during clinical trials and costs covered by payers as “routine care” | - Coverage for routine care varied by payer and state over the last 20 years with Medicaid being the last to adopt coverage in all states.; - Payers can still deny coverage for trials at out-of-network sites.; - The financial burden of direct costs like coinsurance is not addressed by routine care policies. | - There is limited information on what costs are considered routine care by payer.; - There are few studies on the impact of routine care policies and those that do show mixed effects on trial participation.; - No articles discussed the impact of COVID-19 or clinical trial innovations on routine care costs | - What medical costs related to clinical trial participation are not covered by insurance or the trial?; - To what extent do insurers deny coverage of certain medical procedures or test during clinical trials?; - To what extent do insurers consider any of the trial providers or clinical sites to be out-of-network?
Impact of financial and nonfinancial barriers on clinical trial participation among historically underrepresented groups | - Socioeconomic factors (including education level, age, employment status, income level, and insurance status) contribute to observed disparities and present a significant barrier to trial participation, especially for Black and Hispanic patients, patients older than age 65, and rural patients. Nonfinancial barriers include patient awareness, encouragement from providers to participate, regional availability, and ineligibility, including due to age and health status. | - More information on the impact of COVID-19 on barriers to clinical trial enrollment is needed.; - No findings for barriers for pregnant and lactating people, LGBTQIA+ populations, or people with disabilities. | - What are eligibility barriers for patients interested in participating in trials and to what extent they differ for underrepresented groups?; - What are the barriers to trial participation for other underrepresented groups, such as pregnant and lactating people, LGBTQIA+ populations, or people with disabilities?; - How does availability of clinical trials impact patients in rural areas?; - Are there differences in direct and indirect costs for underrepresented groups?
Effect of the COVID-19 and clinical trial innovations like remote monitoring on costs to patients, diversity of trial participants, and barriers to trial participation | - Some patients reported benefits from remote study visits like reduced time commitment and travel costs (qualitative findings only).; - Remote study visits presented some technological challenges for patients and could disadvantage older or low-income patients without reliable internet access. | - There were no cost estimates on the impact of remote study visits or other decentralized trial elements on indirect costs like travel.; - There was limited information on the effects of the following innovations on costs, diversity, and barriers to participation: cost reimbursement, home visits and relaxed follow-up timeframes. | - What is the uptake of remote study visits or use of offsite facilities, like local laboratory or medical office for tests or visits, in clinical trials?; - What is the impact of remote study visits or other clinical trial innovations have on travel costs and financial burden associated with participating in the trial?; - Are there challenges for patients associated with telehealth technology during trials?

Our environmental scan concludes that there is limited research that quantifies direct or indirect costs to patients during clinical trials and no studies on the impact of the COVID-19 pandemic or clinical trial innovations on these costs. Among the available literature, travel costs and patient-reported financial toxicity are most often studied, and much of the literature focused on cancer clinical trials. There were also limited findings on what type of care is considered routine care by insurers during the course of a clinical trial and limited findings on the impacts of COVID-19 on this coverage or associated costs. However, we did find evidence that routine care coverage policies did not address other insurance-related barriers to clinical trial participation like clinical trial sites being considered out-of-network. Finally, we found literature that indicates that Black and Hispanic patients, patients over age 65, and rural patients are less likely to participate in clinical trials. Because differences in socioeconomic factors, like education level, income, and insurance type, may be an underlying cause of these disparities, addressing the cost of participating in clinical trials might have a downstream effect of improving clinical trial participation among these groups. Further information on estimates of direct and indirect costs to patients by clinical trial type (phase and disease) and on differences for underrepresented groups is needed, including among people with disabilities and older adults. Research to estimate the impact of certain clinical trial innovations like the shift to remote monitoring prompted by the COVID-19 pandemic on these costs could inform whether increased uptake of a decentralized trial approach could address financial and nonfinancial barriers to clinical trial participation.

4 See Exhibit III.2 for a breakdown of the different types of costs covered in the literature and the number of articles that discuss each type of cost.