# II Methods

This chapter describes the methods we used for the environmental scan, including our search strategy and our process for reviewing articles.

## A Search strategy

We searched three databases to identify formal literature published from 2010 to 2023 related to the search topics: EBSCO Academic Search Premier, EBSCO Cumulative Index of Nursing and Allied Health Literature (CINAHL), and PubMed. We list some of the key search terms for each research topic in Exhibit II.1. Informed by background literature and feedback provided by ASPE, we chose our search terms to address the four search topics. We included all literature starting in 2010 to capture literature surrounding the Affordable Care Act’s requirement that private insurers cover routine care costs in clinical trials.

Exhibit II.1 Search terms for the database search

Topic Number | Research topic | Search query
1 | Direct and indirect costs to patients in clinical trials | (“financial toxicity” OR “financial burden” OR “cost to patients” OR “direct costs” OR “indirect costs” OR “patient costs” OR “cost to patient” OR “direct cost” OR “indirect cost” OR “patient cost” OR “reduce cost” OR “reduce costs” OR “out-of-pocket“ OR “out-of-pocket”)) AND (“clinical trial” OR “clinical trials”)
2 | Routine care cost policies | Search 1: (payer) OR payor OR Medicaid) OR Medicare or insurance) AND (“clinical trial” OR “clinical trials”) AND (cost*); Search 2: “routine care cost” OR “routine care costs””
3 | Barriers to clinical trial participation for historically underrepresented groups | ((diversity) OR (representation) OR (underrepresented) OR (minority) OR (marginalized) OR (vulnerable) OR (barrier) OR (Hispanic) OR (Black) OR (Latino) OR (Asian) OR (female) OR (women) OR (child) OR (pediatric) OR (race) OR (ethnicity) OR (disability) OR (“older adults”) OR (aging) OR (pregnant) OR (lactating) AND (“financial toxicity” OR “financial burden” OR “cost to patients” OR “direct costs” OR “indirect costs” OR “patient costs” OR “cost to patient” OR “direct cost” OR “indirect cost” OR “patient cost” OR “reduce cost” OR “reduce costs” OR “out-of-pocket” OR “out-of-pocket”)) AND (“clinical trial” OR “clinical trials”)
4 | Effect of COVID-19 on clinical trial costs to patients | (COVID) OR (coronavirus) OR (pandemic) OR (innovation) OR (remote monitoring) OR (decentralized) OR (reform)) AND (clinical trial) AND (“financial toxicity” OR “financial burden” OR “cost to patients” OR “direct costs” OR “indirect costs” OR “patient costs” OR “cost to patient” OR “direct cost” OR “indirect cost” OR “patient cost” OR “reduce cost” OR “reduce costs” OR “out-of-pocket” OR “out-of-pocket” OR (cost))

We also searched the gray literature for resources mentioning key terms using the websites of organizations related to clinical trials or cancer research and advocacy groups, Google, and GoogleScholar. After completing the initial article review, we conducted a backward and forward snowball search using the articles we identified in the first round of the formal literature search to find additional references (see Figure II.1 for a schematic of the article review process). The full search strategy including the search syntax, is available in Appendix A.

## B Article review

Figure II.1 shows the number of articles identified in our search, excluded at each stage, and included in the final analysis. Using the four separate sets of search terms listed in Exhibit II.2, we identified 3,192 articles across the four topics. After a title review (or brief abstract review if unclear from the title) for relevance, we removed 3,076 articles that did not focus on the topics of clinical trials costs to patients or barriers to clinical trial participation.^1^ After an initial screen of the gray literature results, we added 89 relevant articles or sources to the abstract review for a total of 205 articles. Because we found that the literature on clinical trials’ costs to patients is limited, our scan does not focus on a specific subset of clinical trials. However, much of the literature on costs to patients focuses on oncology trials.

Exhibit II.2 Article review flowchart

This figure includes a flowchart for all the articles reviewed in this environmental scan. Topic 1 returned 1,097 articles with the initial search terms. Topic 2 returned 1,144 articles, Topic 3 returned 242 articles, and Topic 4 returned 709 articles. A total of 3,192 had a title review, and we removed 3,076 articles that had unrelated results. 89 additional grey literature items were added to the abstract review for a total of 205 unique abstracts reviewed. 161 articles were removed after abstract review because there was no direct discussion of cost and barriers, result in 44 first round full-texts reviewed. 40 additional full text articles were added to the full text review from a snowball search, yielding a total of 84 final full-text articles reviewed for the environmental scan.

We then reviewed the abstracts for the 205 articles and removed 161 that did not directly discuss costs to patients or barriers to clinical trial participation.^2^ At this point, there were 44 remaining articles from the initial review. We then conducted forward and backward snowball searches to add another 40 full text articles, yielding a total of 84 full text articles or resources included in the final environmental scan.

1 Some examples of articles removed based on title review were cost-effectiveness studies. A few articles had ambiguous titles, such as ”The Current State of Clinical Trials Studying Hydrocephalus: An Analysis of ClinicalTrials.gov (https://pubmed.ncbi.nlm.nih.gov/32983722/)“ (Abraham et al. 2020) but, after a brief review of the abstract, we found that the abstract’s mention of “financial burden” refers to the cost of care to the health system overall, which is not within the scope of the environmental scan.

2 For example, some articles provided commentary on the need for diversifying clinical trials or incorporating patient centered outcomes, such as out-of-pocket costs into trials, but they did not highlight estimates of costs or they cited other articles already included in the full text review, such as the commentary in “Incorporating Patient and Caregiver Experiences into Cardiovascular and Clinical Trial Design (https://jamanetwork.com/journals/jamacardiology/article-abstract/2657319)” (Collins et al. 2017).