# I Introduction

Under the Lessons Learned from the COVID-19 Pandemic contract funded by the Office of the Assistant Secretary for Planning and Evaluation (ASPE), Mathematica is working to better understand how the COVID-19 pandemic might have influenced the costs to patients enrolled in oncology clinical trials. This work includes an environmental scan and the development of a patient survey to inform the following research questions:

1. How did clinical trial innovations and strategies implemented during the COVID-19 pandemic, such as use of remote technologies, impact costs for participating patients?
2. What are the types of costs (direct and indirect) associated with participating in clinical trials? Were the types of costs different during the COVID-19 pandemic?
3. What are the patient costs associated with participating in oncology clinical trials? Did patient costs change over the course of the COVID-19 pandemic?
4. How do costs associated with clinical trial participation differ between sociodemographic groups? Did these costs change over the course of the COVID-19 pandemic?
5. What types of costs are typically not covered by payers? How are these costs different by payer type? Did the types of costs covered by payers change over the course of the COVID-19 pandemic?
6. What types of costs are typically covered by other non-payer organizations such as research centers, sponsors, patient advocacy groups or research institutions, which are not covered by payers? How did the types of costs change over the course of the COVID-19 pandemic?
7. Are there any lessons learned from pandemic-era clinical trial strategies and innovations to reduce costs for patients? What types of financial recruitment incentives might increase diversity in oncology clinical trials?

This environmental scan focuses on the literature that explores the financial and nonfinancial barriers to clinical trial participation, including direct and indirect costs to patients and differences for underrepresented groups. We also reviewed any available literature on the impact of COVID-19 or clinical trial innovations on these barriers. This environmental scan included information on costs and barriers associated with all types of clinical trials. The findings in this environmental scan focus on the following search topics, which touch on all of the research questions above.

- [underlined: Topic 1:] The types of direct and indirect costs to patients associated with clinical trial participation, including any estimates of such costs in the literature.
- [underlined: Topic 2:] Recognizing that payers are required to cover “routine care costs,” the types of costs that are not considered “routine care” or may not be covered by payers, and any impact of COVID-19 or clinical trial innovations on routine care coverage.
- [underlined: Topic 3:] Financial and nonfinancial barriers on participation in clinical trials by sociodemographic groups, with an emphasis on historically underrepresented groups, and the impact of COVID-19 or clinical trial innovations on barriers to participation.
- [underlined: Topic 4:] Any changes in Topics 1 to 3, such as, costs to patients, routine care coverage, or barriers to clinical trial participation, during COVID-19 or because of clinical trial innovations (for example, remote monitoring or decentralized trials).