# Appendix A Complete Search Strategy

We used the following approaches to identify relevant literature, which we organized in Zotero:

1. Searched Elton B. Stephens Co. (EBSCO) Academic Search Premier, EBSCO Cumulative Index of Nursing and Allied Health Literature (CINAHL), and PubMed for peer-reviewed journal articles.
  We list the search query for each research topic and the initial article count in PubMed as of October 24, 2023, for reference below in Exhibit A.1.

Exhibit A.1 Initial PubMed search result counts, by research topic

Topic Number | Search topic | Search query | Initial article count in PubMed
1 | Direct and indirect costs to patients in clinical trials | (“financial toxicity” OR “financial burden” OR “cost to patients” OR “direct costs” OR “indirect costs” OR “patient costs” OR “cost to patient” OR “direct cost” OR “indirect cost” OR “patient cost” OR “reduce cost” OR “reduce costs” OR “out-of-pocket” OR “out-of-pocket”)) AND (“clinical trial” OR “clinical trials”) | 1,078
2 | Routine care cost policies | Search 1: (payer) OR payor OR Medicaid) OR Medicare or insurance) AND (“clinical trial” OR “clinical trials”) AND (cost*) | 1,139
| | Search 2: “routine care cost” OR “routine care costs”” | 17
3 | Barriers to clinical trial participation for historically underrepresented groups | ((divers*) OR (representation) OR (underrepresent*) OR (minorit*) OR (marginalized) OR (vulnerable) OR (barrier*) OR (Hispanic) OR (Black) OR (Latin*) OR (Asian) OR (female*) OR (womenTitle/Abstract]) OR (child*) OR (pediatric*) OR (race) OR (ethnicit*) OR (disabilit*) OR (“older adults”) OR (aging) OR (pregnan*) OR (lactat*) OR (“Health Disparate, Minority and Vulnerable Populations”[Mesh]) OR “Sexual and Gender Minorities”[Mesh]) AND (“financial toxicity” OR “financial burden” OR “cost to patients” OR “direct costs” OR “indirect costs” OR “patient costs” OR “cost to patient” OR “direct cost” OR “indirect cost” OR “patient cost” OR “reduce cost” OR “reduce costs” OR “out-of-pocket” OR “out-of-pocket”)) AND (“clinical trial” OR “clinical trials”OR (“Clinical Trials as Topic”[Mesh])) | 428
4 | Effect of COVID-19 on clinical trial costs to patients | ((“COVID-19”[MeSH Terms]) OR (“SARS-CoV-2”[MeSH Terms]) OR (COVID) OR (coronavirus) OR (pandemic) OR (innovat*) OR (remote monitor*) OR (decentral*) OR (reform*)) AND (clinical trial*) AND (“financial toxicity” OR “financial burden” OR “cost to patients” OR “direct costs” OR “indirect costs” OR “patient costs” OR “cost to patient” OR “direct cost” OR “indirect cost” OR “patient cost” OR “reduce cost” OR “reduce costs” OR “out-of-pocket” OR “out-of-pocket” OR (cost)) | 698

We identified these search terms by reviewing a subset of relevant literature for common terminology. We restricted the search to articles published between 2010 and 2023 for Topics 1, 2, and 3 to focus on findings immediately before and during COVID-19 and between 2020 to 2023 for Topic 4, which focus on the time after the start of the COVID-19 pandemic in 2020. We leveraged Zotero’s de-duplicating function to filter to unique articles across the three databases and then restricted further by reviewing abstracts and excluding articles that met the following criteria:

- Focus on countries other than the United States;
- Do not include results either related to costs to patients, “routine care” costs and coverage, barriers to participation for historically underrepresented groups, or clinical trial innovations during COVID-19.

We prioritized the initial screening of articles by relevance of the title and the final review of full text by relevance of the title and abstract. After applying the exclusion criteria, we expected this approach to yielded 29 peer-reviewed articles across the four topics.

1. Snowball search: We implemented a forward and backward snowball search using the peer-reviewed articles for all topics identified from the initial database search. This approach yielded an additional 20 peer-reviewed articles across the four topics.
2. Search resource pages on websites of key organizations: We conducted focused searches on the websites related to clinical trials and cancer research and advocacy groups for information related costs and barriers associated with clinical trial participation and diversity in clinical trials. Examples include (1) fda.gov with a search for “clinical trial diversity”^5^; (2) nih.gov with a search for “clinical trial diversity”; (3) American Cancer Society (https://www.cancer.org/) with a search for “clinical trial cost”, “treatment cost”, and “care cost”; (4) National Coalition for Cancer Survivorship (https://canceradvocacy.org/) with a search for “clinical trial”; (5) Alliance for Clinical Trials in Oncology (https://www.allianceforclinicaltrialsinoncology.org/main/public/index.xhtml) with a search for “financial toxicity”, “treatment cost”, and “care cost”; (6) Center for Information and Study on Clinical Research Participation with a search for “clinical trial diversity” and “clinical trial cost”, “clinical trial cost”; “treatment cost”, and “care cost” (7) Association of Clinical Research Professionals with a search for “clinical trial cost”, “treatment cost”, and “care cost”; and (8) National Health Council with a search for “clinical trial cost”, “treatment cost”, and “care cost.” This approach yielded 24 relevant articles across the four topics.
3. Google Scholar and Google searches to identify additional grey literature: We conducted broad searches in Google Scholar and in Google to skim for relevant grey literature or data that was not uncovered in previous searches. We applied the same general exclusion criteria to results as in the database searches; however, we did not systematically apply these criteria to each search. Further, the Google searches returned many results and we prioritized those that appeared most relevant by their titles.

For searches in Google Scholar, we used the following search terms and filtered to results since 2010:

– financial toxicity allintitle: clinical trial
– “cost to patients” allintitle: clinical trial
– allintitle: clinical trial diversity
– allintitle: clinical trial underrepresented
– "routine care" policy financial toxicity clinical trials
– allintitle: cancer patient survey cost

For Google searches, we used the following search terms and filtered to results since 2010:

– clinical trial COVID-19 innovation
– "cost to patients" clinical trials
– routine care cost financial toxicity clinical trial
– cost barriers to clinical trial participation
– clinical trial patient survey cost

This approach yielded 37 relevant articles across the four topics.

5 Note: using “cost” as a search term yields many extraneous results regarding the cost of conducting clinical trials rather than the cost to patients, while using the search term “cost to patients” often yields few results. To minimize the number of extraneous results on extensive websites like fda.gov or nih.gov, we focused on grey literature related to clinical trial participation among historically underrepresented groups and found that the search term “diversity” is commonly used.