# References

Abdul-Mutakabbir J.C., Casey S., Jews V., King A., Simmons K., Hogue M.D., Belliard J.C., “A Three-Tiered Approach to Address Barriers to COVID-19 Vaccine Delivery in the Black Community.” Lancet Global Health, vol. 9, no. 6, 2021, pp. e749–e750.33713634
Abdul-Mutakabbir J.C., Granillo C., Peteet B., Dubov A., Montgomery S.B., Hutchinson J., Casey S., "Rapid Implementation of a Community-Academic Partnership Model to Promote COVID-19 Vaccine Equity Within Racially and Ethnically Minoritized Communities." Vaccines, vol. 10, no. 8, 2022.
Abdul-Mutakabbir J.C., Tillman F., Marcelin J.R., Saunders I.M., and Arya V.. "Slowed Progression: The Utility of Test to Treat Initiatives in Improving the Neglected Inequities of COVID-19 Among Racially/Ethnically Minoritized Groups." Journal of the American Pharmacists Association, vol. 63, no. 1, 2023, pp. 424–429. https://doi.org/doi:10.1016/j.japh.2022.10.025.36470731
Administration for Strategic Preparedness and Response (ASPR). “Fact Sheet: COVID-19 Test to Treat.” n.d.a https://aspr.hhs.gov/TestToTreat/Pages/fact-sheet-covid19-t2t.aspx. Accessed March 16, 2023.
ASPR. “Get to know DRIVe.” n.d.b https://drive.hhs.gov/about.html. Accessed April 2023.
ASPR. “Test to Treat.” March 2022. https://aspr.hhs.gov/TestToTreat/Pages/default.aspx. Accessed January 2023.
Alcendor D.J. "Targeting COVID Vaccine Hesitancy in Rural Communities in Tennessee: Implications for Extending the COVID-19 Pandemic in the South." Vaccines, vol. 9, no. 11, 2021.
Alcendor D.J., Juarez P.D., Matthews-Juarez P., Simon S., Nash C., Lewis K., and Smoot D.. "Meharry Medical College Mobile Vaccination Program: Implications for Increasing COVID-19 Vaccine Uptake Among Minority Communities in Middle Tennessee." Vaccines, vol. 10, no. 2, 2022a.
Alcendor D.J., Matthews-Juarez P., Smoot D., Hildreth J.E. K., Tabatabai M., Wilus D., Brown K.Y., "The COVID-19 Vaccine and Pregnant Minority Women in the Us: Implications for Improving Vaccine Confidence and Uptake." Vaccines, vol. 10, no. 12, 2022b.
American Academy of Family Physicians. “Surveying the Effect of the COVID-19 Pandemic on Public Confidence in Vaccines and Vaccine Messengers: Lessons Learned and Challenges Ahead.” October 2021. https://www.aafp.org/dam/AAFP/documents/patient_care/immunizations/vaccine-survey-pandemic.pdf. Accessed April 4, 2023.
American’s Health Insurance Plans. “Health Insurance Providers Commit to Help Millions of Seniors in Underserved Communities Receive COVID Vaccines.” March 3, 2021. https://www.ahip.org/news/press-releases/health-insurance-providers-commit-to-help-millions-of-seniors-in-underserved-communities-receive-covid-vaccines. Accessed January 2023.
American Rescue Plan Act of 2021. H.B. 1319. 117th Cong. 2021.
Anderson L., File T., Marshall J., McElrath K., and Scherer Z.. “New Tool Tracks Vaccination and Vaccine Hesitancy Rates Across Geographies, Population Groups.” 2021. https://www.census.gov/library/stories/2021/04/how-do-covid-19-vaccination-and-vaccine-hesitancy-rates-vary-over-time.html. Accessed March 20, 2023.
Appa A., Chamie G., Sawyer A., Baltzell K., Dippell K., Ribeiro S., Duarte E., "SARS-CoV-2 PCR and Antibody Testing for an Entire Rural Community: Methods and Feasibility of High-Throughput Testing Procedures." Archives of Public Health, vol. 79, no. 1, 2021, pp. 125.34233752
Association of American Medical Colleges. “Vaccine Vans: Bringing COVID-19 Testing and Vaccination to an Underserved Community in Brooklyn.” October 2022. http://web.archive.org/web/20230321010907/https:/www.aamc.org/resource-library/collaborative-student-volunteer-and-service-projects/vaccine-vans-bringing-covid-19-testing-and-vaccination-underserved-community-brooklyn. Accessed April 11, 2023.
Association of Public Health Laboratories (APHL). “About COVID-19 Testing.” (n.d.). https://www.aphl.org/programs/preparedness/Crisis-Management/COVID-19-Response/Pages/About.aspx. Accessed March 16. 2023.
Health Atrium. “Atrium Health Expands Access to COVID-19 Testing in Underserved and Minority Communities.” April 2020. https://atriumhealth.org/about-us/newsroom/news/2020/04/atrium-health-expands-access-to-covid19-testing-in-underserved-and-minority-communities. Accessed January 2023.
AuYoung M., Rodriguez Espinosa P., Chen W.T., Juturu P., Young M. T., Casillas A., Adkins-Jackson P., "Addressing Racial/Ethnic Inequities in Vaccine Hesitancy and Uptake: Lessons Learned from the California Alliance against COVID-19." Journal of Behavioral Medicine, 2022, pp. 1–14.34379236
Baillargeon J., Polychronopoulou E., Kuo Y.F., Raji M.A.. “The Impact of Substance Use Disorder on COVID-19 Outcomes.” Psychiatr Serv. vol. 72, no.5, 2021, pp. 578–58.33138712
Baker D.R., Cadet K., and Mani S.. "COVID-19 Testing and Social Determinants of Health Among Disadvantaged Baltimore Neighborhoods: A Community Mobile Health Clinic Outreach Model." Population Health Management, vol. 24, no. 6, 2021, pp. 657–663.34030489
Barrett E.S., Andrews T.R., Roy J., Greenberg P., Ferrante J.M., Horton D.B., Gordon M., "Community- Versus Health Care Organization-Based Approaches to Expanding at-Home COVID-19 Testing in Black and Latino Communities, New Jersey, 2021." American Journal of Public Health, vol. 112, 2022, pp. s918–s922.36265092
Barry K., McCarthy M., Melikian G., Almeida-Monroe V., Leonard M., and De Groot A.S.. "Responding to COVID-19 in an Uninsured Hispanic/Latino Community: Testing, Education and Telehealth at a Free Clinic in Providence." Rhode Island Medical Journal, vol. 103, no. 9, 2020, pp. 41–46.
Barry V., Dasgupta S., Weller D.L., Kriss J.L., Cadwell B.L., Rose C., Pingali C., “Patterns in COVID-19 Vaccination Coverage, by Social Vulnerability and Urbanicity — United States, December 14, 2020–May 1, 2021.” Morbidity and Mortality Weekly Report, vol. 70, no. 22, 2021, pp. 818–824.34081685
Bennett S. “American Indians have the highest Covid vaccination rate in the US.” 2021. https://www.pbs.org/wgbh/nova/article/native-americans-highest-covid-vaccination-rate-us/.Accessed April 12, 2023.
Berkley-Patton J., Thompson C.B., Templeton T., Burgin T., Derose K. P., Williams E., Thompson F., "COVID-19 Testing in African American Churches Using a Faith-Health-Academic Partnership." American Journal of Public Health, vol. 112, 2022, pp. S887–s891.36265094
Berner L., Meehan A., Kenkel J., Montgomery M., Fields V., Henry A., Boyer A., "Clinic- and Community-Based SARS-CoV-2 Testing Among People Experiencing Homelessness in the United States, March-November 2020." Public Health Reports, vol. 137, no. 4, 2022, pp. 764–773.35403502
Beste L.A., Chen A., Geyer J., Wilson M., Schuttner L., Wheat C., Rojas J., "Best Practices for an Equitable COVID-19 Vaccination Program." NEJM Catalyst, vol. 2, no. 10, 2021.
Bigelow B.F., Saxton R.E., Flores-Miller A., Mostafa H.H., Loss M.J., Phillips K.H., Moore A.M., "Community Testing and SARS-CoV-2 Rates for Latinxs in Baltimore." American Journal of Preventive Medicine, vol. 60, no. 6, 2021, pp. e281–e286.33775510
Bigelow B.F., Saxton R.E., Martínez D.A., Flores-Miller A., Shin J.M., Parent C., Williams S., "High Uptake and Series Completion of COVID-19 Vaccine at Community-Based Vaccination for Latinos with Limited English Proficiency." Journal of Public Health Management and Practice, vol. 28, no. 6, 2022, pp. E789–E794.36074797
Bogdewic S., Ramaswamy R.. “Developing Complexity-Informed COVID-19 Responses to Optimize Community Well-Being: A Systems Thinking Approach.” Systems, vol. 9, no. 68, 2021.
Boyd A. D., and Buchwald D.. "Factors That Influence Risk Perceptions and Successful COVID-19 Vaccination Communication Campaigns with American Indians" Science Communication, vol. 44, no. 1, 2022, pp. 130–139.35937962
Braveman P. A., Arkin E., Proctor D., Kauh T., and Holm N.. “Systemic And Structural Racism: Definitions, Examples, Health Damages, And Approaches To Dismantling: Study examines definitions, examples, health damages, and dismantling systemic and structural racism.” Health Affairs, vol. 41, num. 2, 2022, pp. 171–178.35130057
Brown L., Billings V., Pilkington W., and Kumar D.. "Facilitating COVID-19 Testing in Historically Marginalized Populations by Leveraging Community Partnerships." North Carolina Medical Journal, vol. 82, no. 4, 2021, pp. 301.34230190
Brown-DeVeaux D.V., Richards B.R., Gilles S., and Johnson J.. "The Impact of African-American Nurses: How the Implementation of a Community-Based Model Increased Vaccination Rates in Marginalized Communities in NYC." Journal of National Black Nurses Association, vol. 32, no. 2, 2021, pp. 23–27.
Budhwani H., Maragh-Bass A.C., Tolley E.E., Comello M.L. G., Stoner M.C. D., Adams Larsen M., Brambilla D., "Tough Talks COVID-19 Digital Health Intervention for Vaccine Hesitancy Among Black Young Adults: Protocol for Hybrid Type 1 Effectiveness Implementation Randomized Controlled Trial." JMIR Research Protocols, 2023.
Burki T. “Increasing COVID-19 vaccine uptake in Black Americans.” The Lancet, vol. 21, 2021, pp.1500–1501.34717810
Buro A.W., Roman Candelaria K., Bailey R., Luna F., Albizu-Jacob A., Stern M., and Redwine L.. "Exploration of Multilevel Barriers and Strategies That Affected Early COVID-19 Vaccination and Testing in Rural Latino Communities in Southwest Florida." International Journal of Environmental Research and Public Health, vol. 19, no. 18, 2022. https://doi.org/doi:10.3390/ijerph191811785.
Centers for Disease Control and Prevention (CDC). “Seasonal Influenza (Flu) Vaccination and Preventable Disease.” 2016. https://www.cdc.gov/vaccines/vpd/flu/index.html. Accessed March 16, 2023.
CDC. “Equity in Adult Vaccination.” 2020a. https://www.cdc.gov/vaccines/health-equity/index.html.Accessed April 12, 2023.
CDC. “Evaluating and Reporting Persons Under Investigation (PUI).” 2020b. https://stacks.cdc.gov/view/cdc/85453. Accessed March 16, 2023.
CDC. “Evaluating and Testing Persons for Coronavirus Disease 2019 (COVID-19).” 2020c. https://stacks.cdc.gov/view/cdc/85933. Accessed March 16, 2023.
CDC. “Overview of Testing for SARS-CoV-2.” 2020d. https://web.archive.org/web/20200614014804/https:/www.cdc.gov/coronavirus/2019-ncov/hcp/testing-overview.html. Accessed March 16, 2023.
CDC. “Risk of Exposure to COVID-19.” 2020e. http://web.archive.org/web/20230605045026/https://www.cdc.gov/coronavirus/2019-ncov/community/health-equity/racial-ethnic-disparities/increased-risk-exposure.html. Accessed August 18, 2023.
CDC. “CDC Announces $2.25 Billion to Address COVID-19 Health Disparities in Communities that are at High-Risk and Underserved.” 2021a. https://www.cdc.gov/media/releases/2021/p0317-COVID-19-Health-Disparities.html. Accessed January 2023.
CDC. “CDC Crisis Response Cooperative Agreement: COVID-19 Public Health Workforce Supplemental Funding Guidance.” 2021b. https://www.cdc.gov/orr/readiness/00_docs/cdc_crisis_response_covid_19_funding_ph_workforce_guidance_may_2021.pdf. Accessed March 16, 2023.
CDC. “CDC Expands Eligibility for COVID-19 Booster Shots.” 2021c. https://www.cdc.gov/media/releases/2021/p1021-covid-booster.html. Accessed March 16, 2023.
CDC. “CDC-RFA-OT21–2103. National Initiative to Address COVID-19 Health Disparities Among Populations at High-Risk and Underserved, Including Racial and Ethnic Minority Populations and Rural Communities Department of Health and Human Services.” 2021d. https://www.grants.gov/web/grants/view-opportunity.html?oppId=332034. Accessed March 16, 2023.
CDC. “COVID-19 Vaccination Supplemental Funding: Funding for the Implementation and Expansion of the COVID-19 Vaccination Program.” 2021e. https://www.cdc.gov/vaccines/covid-19/downloads/vaccination-supplemental-funding.pdf. Accessed April 11, 2023.
CDC. “COVID-19 Vaccination Supplement 4 (April 2021).” 2021f. https://www.cdc.gov/vaccines/covid-19/downloads/COVID-19-Vaccination-Supplemental-4-Guidance.pdf. Accessed April 11, 2023.
CDC. “Interim Public Health Recommendations for Fully Vaccinated People.” 2021g. https://web.archive.org/web/20210730122824/https:/www.cdc.gov/coronavirus/2019-ncov/vaccines/fully-vaccinated-guidance.html#previous. Accessed March 16, 2023.
CDC. “Overview of Testing for SARS-CoV-2 (COVID-19).” 2021h. http://web.archive.org/web/20210603042942/https:/www.cdc.gov/coronavirus/2019-ncov/hcp/testing-overview.html. Accessed March 16, 2023.
CDC. “CDC COVID-19 Response Health Equity Strategy: Accelerating Progress Towards Reducing COVID-19 Disparities and Achieving Health Equity.” 2022a. https://www.cdc.gov/coronavirus/2019-ncov/community/health-equity/cdc-strategy.html. Accessed March 16, 2023.
CDC. “COVID-19 by County.” 2022b. https://www.cdc.gov/coronavirus/2019-ncov/your-health/covid-by-county.html. Accessed March 16. 2023.
CDC. “COVID-19 Testing: What You Need to Know.” 2022c. https://www.cdc.gov/coronavirus/2019-ncov/symptoms-testing/testing.html. Accessed August 18, 2023.
CDC. “FAQ: COVID-19 Data and Surveillance.” 2022d. https://www.cdc.gov/coronavirus/2019-ncov/covid-data/faq-surveillance.html. Accessed March 16, 2023.
CDC. “Operation Expanded Testing.” 2022e. https://stacks.cdc.gov/view/cdc/119671. Accessed August 18, 2023.
CDC. “Overview of COVID-19 Vaccines.” 2022f. https://www.cdc.gov/coronavirus/2019-ncov/vaccines/different-vaccines/overview-COVID-19-vaccines.html#janssen-when-to-consider. Accessed March 17, 2023.
CDC. “Overview of Testing for SARS-CoV-2, the Virus That Causes COVID-19.” 2022g. https://www.cdc.gov/coronavirus/2019-ncov/hcp/testing-overview.html. Accessed March 16, 2023.
CDC. “Risk of COVID-19-Related Mortality.” 2022h. https://www.cdc.gov/coronavirus/2019-ncov/science/data-review/risk.html. Accessed March 20, 2023.
CDC. “Science Brief: Indicators for Monitoring COVID-19 Community Levels and Making Public Health Recommendations.” 2022i. https://www.cdc.gov/coronavirus/2019-ncov/science/science-briefs/indicators-monitoring-community-levels.html. Accessed May 2, 2023.
CDC. “State of Vaccine Confidence Insights Report: Routine Immunizations on the Schedule for Everyone.” 2022j. https://www.cdc.gov/vaccines/covid-19/downloads/SoVC-RISE-report-11-17-22.pdf. Accessed April 4, 2023.
CDC. “Testing Strategies for SARS-CoV-2.” 2022k. http://web.archive.org/web/20230316154916/https://www.cdc.gov/coronavirus/2019-ncov/lab/resources/sars-cov2-testing-strategies.html. Accessed August 18, 2023.
CDC. “12 COVID-19 Vaccination Strategies for Your Community.” 2022l. https://www.cdc.gov/vaccines/covid-19/vaccinate-with-confidence/community.html. Accessed January 2023.
CDC. “CDC Museum COVID-19 Timeline.” 2023a. https://www.cdc.gov/museum/timeline/covid19.html (https://www.cdc.gov/museum/timeline/covid19.html.Accessed).Accessed March 16, 2023.
CDC. “Flu Vaccination Coverage Update.” 2023b. https://www.cdc.gov/flu/spotlights/2022-2023/flu-vaccine-update.htm. Accessed April 11, 2023.
CDC. “Health Equity.” 2023c. https://www.cdc.gov/coronavirus/2019-ncov/community/health-equity/index.html. Accessed March 16, 2023
CDC. “Risk for COVID-19 Infection, Hospitalization, and Death By Age Group.” 2023d. http://web.archive.org/web/20230320071643/https:/www.cdc.gov/coronavirus/2019-ncov/covid-data/investigations-discovery/hospitalization-death-by-age.html. Accessed August 18, 2023.
CDC. “Stay Up to Date with COVID-19 Vaccines Including Boosters.” 2023e. https://www.cdc.gov/coronavirus/2019-ncov/vaccines/stay-up-to-date.html. Accessed March 17, 2023.
CDC. “Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals.” 2023f.https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html. Accessed March 20, 2023.
CDC. “National Initiative to Address COVID-19 Health Disparities Among Populations at High-Risk and Underserved, Including Racial and Ethnic Minority Populations and Rural Communities.” 2023g. https://www.cdc.gov/publichealthgateway/partnerships/COVID-19-Health-Disparities-OT21-2103.html. Accessed March 16, 2023.
CDC. “The Federal Retail Pharmacy Program for COVID-19 Vaccination.” 2023h. https://www.cdc.gov/vaccines/covid-19/retail-pharmacy-program/index.html. Accessed April 11, 2023.
Centene Corporation. “Understanding Why Underserved Populations are Disproportionately Impacted by COVID-19.” June 15, 2020. https://www.centene.com/news/underserved-populations-disproportionately-impacted-by-covid-19.html. Accessed August 18, 2023.
Center for Evaluation Innovation, Institute for Foundation and Donor Learning, Dorothy A Johnson Center for Philanthropy, Luminare Group. “Equitable Evaluation Framework (EEF) Framing Paper.” Equitable Evaluation Initiative, July 2017. www.equitableeval.org. Accessed May 1, 2023.
Chamie G., Prado P., Oviedo Y., Vizcaíno T., Arechiga C., Marson K., Carrera O., "Reproducibility and Implementation of a Rapid, Community-Based COVID-19 ‘Test and Respond’ Model in Low-Income, Majority-Latino Communities in Northern California." PloS One, vol. 17, no. 10, 2022, pp. e0276257.36301834
Chidambaram P., Garfield R.. “COVID-19 Cases and Deaths in Long-Term Care Facilities through June 2021” 2021. https://www.kff.org/coronavirus-covid-19/issue-brief/covid-19-cases-and-deaths-in-long-term-care-facilities-through-june-2021/. Accessed April 12, 2023.
Chidavaenzi N.Z., Agathis N., Lees Y., Stevens H., Clark J., Reede D., Kunkel A., "Implementation of a COVID-19 Screening Testing Program in a Rural, Tribal Nation: Experience of the San Carlos Apache Tribe, January–February 2021." Public Health Reports, vol. 137, no. 2, 2022, pp. 220–225. =35023417
Choi K., Romero R., Guha P., Sixx G., Rosen A. D., Frederes A., Beltran J., "Community Health Worker Perspectives on Engaging Unhoused Peer Ambassadors for COVID-19 Vaccine Outreach in Homeless Encampments and Shelters." Journal of General Internal Medicine, vol. 37, no. 8, 2022, pp. 2026–2032.35411533
CMS. “Biden-Harris Administration Requires Insurance Companies and Group Health Plans to Cover the Cost of At-Home COVID-19 Tests, Increasing Access to Free Tests.” 2022a. https://www.cms.gov/newsroom/press-releases/biden-harris-administration-requires-insurance-companies-and-group-health-plans-cover-cost-home. Accessed March 16, 2023.
CMS. “A Guide to Using the Accountable Health Communities Health-Related Social Needs Screening Tool: Promising Practices and Insights.” 2022b. https://innovation.cms.gov/media/document/ahcmscreeningtool-companion. Accessed May 8, 2023.
Collins F. “Learning to Protect Communities with COVID-19 Home Testing Programs.” 2021. https://directorsblog.nih.gov/2021/10/07/learning-to-protect-communities-with-covid-19-home-testing-programs/. Accessed March 16, 2023.
Corneli A., McKenna K., Dombeck C., Molokwu N., Taylor J., Vergara L., Benjamin D. K. Jr., "Caregivers of Black and Latino/a/X Students and School Personnel Perspectives on School-Based SARS-CoV-2 Testing: Implications for Testing and Test-to-Stay Programs In k-12 Schools." Journal of School Health, 2022.
Coronavirus Aid, Relief, and Economic Security Act. H.R. 748. 116th Cong. 2020.
Crane J.T., Fabi R., Pacia D., Neuhaus C. P., and Berlinger N.. “‘We're Here to Take Care of Our Community’: Lessons Learned from the U.S. Federal Health Center COVID-19 Vaccine Program." Health Promotion Practice, 2023.
Crist C. “CDC: Fully Vaccinated Can Skip Routine COVID Testing.” 2021. http://web.archive.org/web/20221130005921/https:/www.webmd.com/vaccines/covid-19-vaccine/news/20210604/cdc-says-fully-vaccinated-can-skip-routine-covid-testing. Accessed August 18, 2023.
Coones S. "Prominent Pastor, Scientists, Researchers Seek to Ease Vaccine Fears in Minority Populations." IRB Advisor, vol. 21, no. 3, 2021, pp. 1–5.
Cuadros D.F., Branscum A.J., Mukandavire Z., Miller F.D., and MacKinnon N.. “Dynamics of the COVID-19 Epidemic in Urban and Rural Areas in the United States.” Annals of Epidemiology, vol. 59, 2021, pp. 16–20.33894385
Cybersecurity and Infrastructure Security Agency (CISA). “Guidance on essential critical infrastructure workers: version 4.0.” 2020. https://www.cisa.gov/publication/guidance-essential-critical-infrastructure-workforce. Accessed May 2, 2023.
Davis T., Singh J., Lance J. G., Latiolais L., Kevil C., Bodily J., Sapp M., "COVID-19 Community Testing in Rural Areas: A Partnership between an Academic Medical Center and Community Clinics." Journal of Community Medicine & Health Education, vol. 10, no. 4, 2020.
Deerin J.F., Gyekye-Kusi A.A., Doss-Walker J., Bablak H., and Kim D.. "Evaluation of ‘Catch up to Get Ahead’ Efforts on Administration of Routine Childhood Vaccinations During COVID-19 Pandemic, United States Indian Health Service, 2020." Journal of Public Health Policy, vol. 43, no. 4, 2022, pp. 613–620.36352258
DeGarmo D.S., De Anda S., Cioffi C.C., Tavalire H.F., Searcy J.A., Budd E.L., Hawley McWhirter E., "Effectiveness of a COVID-19 Testing Outreach Intervention for Latinx Communities: A Cluster Randomized Trial." JAMA Network Open, vol. 5, no. 6, 2022.
Demeke J., McFadden S.M., Dada D., Djiometio J.N., Vlahov D., Wilton L., Wang M., "Strategies That Promote Equity in COVID-19 Vaccine Uptake for Undocumented Immigrants: A Review." Journal of Community Health, vol. 47, no. 3, 2022a, pp. 554–562.35084639
Demeke J., Ramos S.R., McFadden S.M., Dada D., Nguemo Djiometio J., Vlahov D., Wilton L., "Strategies That Promote Equity in COVID-19 Vaccine Uptake for Latinx Communities: A Review." Journal of Racial and Ethnic Health Disparities, 2022b, pp. 1–9.
DeSalvo K., Hughes B., Bassett M., Benjamin G., Fraser M., Galea S., and Gracia J.N.. “Public Health COVID-19 Impact Assessment: Lessons Learned and Compelling Needs.” NAM Perspectives. April 2021.
Dooling K., Marin M., Wallace M., McClung N., Chamberland M., Lee G.M., Talbot H.K., “The Advisory Committee on Immunization Practices’ Updated Interim Recommendation for Allocation of COVID-19 Vaccine — United States, December 2020.” Morbidity and Mortality Weekly Report, vol. 69, 2021, pp. 1657–1660.33382671
Dumproff J.B., Bishara J., Copeland N., and Fredricks T.. "Integrating U.S. National Guard with Public Health Partners at COVID-19 Testing Sites in West Virginia Counties with High Rural and Minority Populations: Lessons Learned." Health Security, vol. 20, no. 1, 2022, pp. 58–64.35021896
Egede L.E., and Walker R.J.. “Structural racism, social risk factors, and Covid-19—a dangerous convergence for Black Americans.” New England Journal of Medicine, vol. 383, no. 12, 2020, pp. e77.32706952
Evans A., Webster J., and Flores G.. "Partnering with the Faith-Based Community to Address Disparities in COVID-19 Vaccination Rates and Outcomes Among Us Black and Latino Populations." JAMA, vol. 326, no. 7, 2021, pp. 609–610.34402817
Faherty L.J., Ringel J.S., Williams M.V., Kranz A.M., Perez L., Schulson L.B., Gittens A.D., “The U.S. Equity-First Vaccination Initiative: Early Insights.” Santa Monica, CA: RAND Corporation, 2021.
Faherty L.J., Ringel J.S., Kranz A.M., Baker L., Phillips B., Williams M.V., Perez L., “Putting Equity First in COVID-19 Vaccination.” Santa Monica, CA: RAND Corporation, 2022.
Falope O., Nyaku M.K., O’Rourke C., Hermany L. V., Plavchak B., Mauskopf J., Hartley L., and Kruk M.E.. “Resilience Learning from the COVID-19 Pandemic and Its Relevance for Routine Immunization Programs.” Expert Review of Vaccines, vol. 22, no. 11.
Feagin J.R., Ducey K. Racist America. Routledge, 2018.
Federal Emergency Management Agency. “FEMA Funds Community Engagement for COVID-19 Vaccinations.” May 2021. https://www.fema.gov/fact-sheet/fema-funds-community-engagement-covid-19-vaccinations. Accessed August 18, 2023.
Feifer Richard A., Bethea LaShuan, and White Elizabeth M.. "Racial Disparities in COVID-19 Vaccine Acceptance: Building Trust to Protect Nursing Home Staff and Residents." Journal of the American Medical Directors Association, vol. 22, no. 9, 2021, pp. 1853–1853.34375655
Feuer W. “CDC Reverses Controversial Coronavirus Guidance That Said People Without Symptoms May Not Need a Test.” 2020. https://www.cnbc.com/2020/09/18/cdc-reverses-coronavirus-guidance-that-said-people-without-symptoms-may-not-need-a-test.html. Accessed March 16, 2023.
Food and Drug Administration (FDA). “Screening for COVID-19: Deciding Which Test to Use When Establishing Testing Programs.” n.d.(a). https://www.fda.gov/media/146666/download. Accessed March 16, 2023.
FDA. “COVID-19 Test Basics.” n.d.(b). https://www.fda.gov/consumers/consumer-updates/covid-19-test-basics. Accessed March 16. 2023.
FDA. “COVID-19 Vaccines.” n.d.(c). https://www.fda.gov/emergency-preparedness-and-response/coronavirus-disease-2019-covid-19/covid-19-vaccines#authorized-vaccines. Accessed March 17, 2023.
FDA. “Coronavirus (COVID-19) Update: FDA Issues New Policy to Help Expedite Availability of Diagnostics.” 2020. https://www.fda.gov/news-events/press-announcements/coronavirus-covid-19-update-fda-issues-new-policy-help-expedite-availability-diagnostics. Accessed March 16, 2023.
FDA. “FDA Authorizes Pfizer-BioNTech COVID-19 Vaccine for Emergency Use in Children 5 Through 11 Years of Age.” 2021. https://www.fda.gov/news-events/press-announcements/fda-authorizes-pfizer-biontech-covid-19-vaccine-emergency-use-children-5-through-11-years-age. Accessed March 16, 2023.
FDA. “At-Home COVID-19 Antigen Tests-Take Steps to Reduce Your Risk of False Negative Results: FDA Safety Communication.” 2022a. https://www.fda.gov/medical-devices/safety-communications/home-covid-19-antigen-tests-take-steps-reduce-your-risk-false-negative-results-fda-safety. Accessed March 16, 2023.
FDA. “Coronavirus (COVID-19) Update: FDA Authorizes Moderna and Pfizer-BioNTech Bivalent COVID-19 Vaccines for Use as a Booster Dose in Younger Age Groups.” 2022b. https://www.fda.gov/news-events/press-announcements/coronavirus-covid-19-update-fda-authorizes-moderna-and-pfizer-biontech-bivalent-covid-19-vaccinesAccessed March 16, 2023.
FDA. “Coronavirus (COVID-19) Update: FDA Authorizes Moderna and Pfizer-BioNTech COVID-19 Vaccines for Children Down to 6 Months of Age.” 2022c. Coronavirus (COVID-19) Update: FDA Authorizes Moderna and Pfizer-BioNTech COVID-19 Vaccines for Children Down to 6 Months of Age | FDA. Accessed March 16, 2023.
FDA. “Coronavirus (COVID-19) Update: FDA Expands Eligibility for Pfizer-BioNTech COVID-19 Vaccine Booster Dose to Children 5 Through 11 Years.” 2022d. https://www.fda.gov/news-events/press-announcements/coronavirus-covid-19-update-fda-expands-eligibility-pfizer-biontech-covid-19-vaccine-booster-dose. Accessed March 16, 2023.
FDA. “Coronavirus (COVID-19) Update: FDA Authorizes Bivalent Pfizer-BioNTech COVID-19 Vaccine as Booster Dose for Certain Children 6 Months Through 4 Years of Age.” 2023. https://www.fda.gov/news-events/press-announcements/coronavirus-covid-19-update-fda-authorizes-bivalent-pfizer-biontech-covid-19-vaccine-booster-dose. Accessed March 16, 2023.
Gaffney A., Woolhandler S., and Himmelstein D.U.. “COVID-19 Testing and Incidence Among Uninsured and Insured Individuals in 2020: a National Study.” Journal of General Internal Medicine, vol. 37, no. 5, 2022, pp. 1344–1347.35141855
Gillwald K., Lee S.H., Paegle A., Mead P., Acker T., Roberts N.B., and Dunn A.C.. "Rapid COVID-19 Testing and on-Site Case Investigation and Contact Tracing in an Underresourced Area of Salt Lake City, Utah, December 2020-April 2021." Public Health Reports, vol. 137, no. 2, 2022, pp. 56s–60s.36073309
Gleason J., Ross W., Fossi A., Blonsky H., Tobias J., Stephens M.. “The Devastating Impact of Covid-19 on Individuals with Intellectual Disabilities in the United States.” NEJM Catalyst, vol. 2, no. 2, 2021.
Goldberg S.A., Bonacci R.A., Carlson L.C., Pu C.T., and Ritchie C.S.. "Home-Based Testing for SARS-CoV-2: Leveraging Prehospital Resources for Vulnerable Populations." Western Journal of Emergency Medicine: Integrating Emergency Care with Population Health, vol. 21, no. 4, 2020, pp. 813–816.
Gregory N. "COVID-19 Vaccines in Tribal Communities Save Lives, Preserve Culture." American Journal of Health-System Pharmacy, vol. 78, no. 10, 2021, pp. 835–839.
Gilmore B., Ndejjo R., Tchetchia A., de Claro V., Mago E., Diallo A., “Community engagement for COVID-19 prevention and control: a rapid evidence synthesis.” BMJ Global Health, vol. 5, 2020, pp. e003188.
Gonzales A., Lee E.C., Grigorescu V., Smith S.R., de Lew N., and Sommers B.D.. “Overview of Barriers and Facilitators in COVID-19 Vaccine Outreach.” Assistant Secretary for Planning and Evaluation, Office of Health Policy, 2021. https://aspe.hhs.gov/reports/covid-19-vaccine-outreach. Accessed April 14, 2023.
Gumbrecht J., Howard J., Fox M., and Bonifield J.. “CDC Recommends COVID-19 Boosters for All Adults.” CNN, 2021. https://www.cnn.com/2021/11/19/health/covid-vaccine-boosters-fda-cdc/index.html.Accessed March 16, 2023.
Gupta P.S., Mohareb A.M., Valdes C., Price C., Jollife M., Regis C., Munshi N., "Mobile Health Services for COVID-19: Counseling, Testing, and Vaccination for Medically Underserved Populations." American Journal of Public Health, vol. 112, no. 11, 2022, pp. 1556–1559.36223583
Guzman J. “CDC: People Exposed to Coronavirus but Have No Symptoms May Not Need to Be Tested.” 2020. https://thehill.com/changing-america/well-being/prevention-cures/513710-cdc-people-exposed-to-coronavirus-but-have-no/. Accessed March 16, 2023.
Hacker K., Auerbach J., Ikeda R., Philip C., and Houry D.. “CDC’S Approach to Social Determinants of Health.” 2022.https://jphmpdirect.com/2022/10/07/cdcs-approach-to-social-determinants-of-health/?utm_source=BHPN+Website+Newsletter+List&utm_campaign=c46a03e0a4-EMAIL_CAMPAIGN_2019_12_19_07_21_COPY_01&utm_medium=email&utm_term=0_c39fafc581-c46a03e0a4-356406371. Accessed March 20, 2023.
Hansotte E., Bowman E., Gibson P.J., Dixon B. E., Madden V.R., and Caine V.A.. "Supporting Health Equity through Data-Driven Decision-Making: A Local Health Department Response to COVID-19." American Journal of Public Health, vol. 111, 2021, pp. S197–S200.34709872
Haroun A., and Brueck H.. “The CDC Quietly Changed Its Guidance to Say Even Vaccinated People Should Get Tested If They've Been Exposed to COVID-19.” 2021. https://news.yahoo.com/cdc-quietly-changed-guidance-even183418244.html?guccounter=1&guce_referrer=aHR0cHM6Ly93d3cuYmluZy5jb20v&guce_referrer_sig=AQAAANQVElXrSkCEWhaGp-B4cs71XSTxO2B6mmUMNCMCzup3cXO4zfigvs-A27O74kuTFT-VMpjSIqFPCXrV9iZqhXEKSlKQNWDa_pc9BChBTyJGJ-3jre8sYz4J1xCREBw1frqI5URhfi75ZI-CLZXzcDPQLqL80kreiIiZscaCoQkw. Accessed March 16, 2023.
Harvard T.H. Chan School of Public Health. “NIH Funding to Help Researchers Scale Up COVID-19 Testing in Underserved Communities.” October 7, 2020. https://www.hsph.harvard.edu/news/features/nih-funding-to-help-researchers-scale-up-covid-19-testing-in-underserved-communities/. Accessed April 12, 2023.
Hill H.A., Chen M., Elam-Evans L.D., Yankey D., Singleton J. A.. “Vaccination Coverage by Age 24 Months Among Children Born During 2018–2019 — National Immunization Survey–Child, United States, 2019–2021.” Morbidity and Mortality Weekly Report, vol. 72, no.2, 2023, pp.33–38.36634013
Health Resources and Services Administration (HRSA). “Rural Tribal COVID-19 Response Program.” April 2020. https://www.hrsa.gov/grants/find-funding/HRSA-20-135#:~:text=What%20is%20the%20program%3F,disease%20(COVID%2D19). Accessed January 2023.
HRSA. “COVID-19 Coverage Assistance Fund.” March 2021. https://www.hrsa.gov/provider-relief/about/covid-19-coverage-assistance. Accessed January 2023.
HRSA. “Community-Based Outreach to Build COVID-19 Vaccine Confidence.” 2022a. https://www.hrsa.gov/coronavirus/community-based-outreach. Accessed March 17, 2023.
HRSA. “COVID-19 Claims Reimbursement to Health Care Providers and Facilities for Testing, Treatment, and Vaccine Administration for the Uninsured.” 2022b. https://www.hrsa.gov/providerrelief/about/covid-uninsured-claim#:~:text=Health%20care%20providers%20who%20have,rates%2C%20subject%20to%20available%20funding. Accessed January 2023.
HRSA. “Ensuring Equity in COVID-19 Vaccine Distribution.” 2022c. https://www.hrsa.gov/coronavirus/health-center-program. Accessed March 17, 2023.
HRSA. “Rural Health Clinic (RHC) COVID-19 Programs.” 2022d. https://www.hrsa.gov/sites/default/files/hrsa/coronavirus/rhc-covid-program-activities-infographic.pdf. Accessed March 17, 2023.
HRSA. “Rural Health Clinic COVID-19 Testing and Mitigation (RHCCTM) Program.” 2022e. https://www.hrsa.gov/coronavirus/rural-health-clinics/testing. Accessed March 16, 2023.
HRSA. “Rural Health Clinic Vaccine Confidence (RHCVC) Program.” February 2022f. https://www.hrsa.gov/coronavirus/rural-health-clinics/confidence. Accessed April 12, 2023.
HRSA. “Rural Health Clinic COVID-19 Vaccine Distribution (RHCVD) Program.” February 2022g. https://www.hrsa.gov/coronavirus/rural-health-clinics/distribution. Accessed April 12, 2023.
HRSA. “Expanding Access to COVID-19 Testing Supplies.” 2023. https://www.hrsa.gov/coronavirus/testing-supplies. Accessed March 16, 2023.
Hernandez J.H., Karletsos D., Avegno J., and Reed C.H.. "Is COVID-19 Community Level Testing Effective in Reaching At-Risk Populations? Evidence from Spatial Analysis of New Orleans Patient Data at Walk-up Sites." BMC Public Health, vol. 21, no. 1, 2021, pp. 632. https://doi.org/doi:10.1186/s12889-021-10717-9.33789647
Illinois Department of Public Health. “IDPH Announces Distribution of 1 Million Free COVID-19 Rapid Tests for Vulnerable Illinoisans.” November 2022. https://dph.illinois.gov/resource-center/news/2022/november/idph-announces-distribution-of-1-million-free-covid-19-rapid-tes.html. Accessed January 2023.
Isasi F., Naylor M.D., Skorton D., Grabowski D.C., Hernandez S., and M Rice V.. “Patients, Families, and Communities COVID-19 Impact Assessment: Lessons Learned and Compelling Needs.” NAM Perspectives, vol. 2021, November 2021. https://doi.org/doi:10.31478/202111c
Islam S.J., Nayak A., Hu Y., Mehta A., Dieppa K., Almuwaqqat Z., Ko Y., “Temporal Trends in the Association of Social Vulnerability and Race/Ethnicity with County-Level COVID-19 Incidence and Outcomes in the USA: An Ecological Analysis.” BMJ Open, vol. 11, 2021, p. e048086.
Jaklevic M.C. "Surgeon Fills COVID-19 Testing Gap in Philadelphia's Black Neighborhoods." JAMA, vol. 325, no. 1, 2021, pp. 14–16. https://doi.org/doi:10.1001/jama.2020.22796.33326010
Jain B., Paguio J.A., Yao J.S., Jain U., Dee E.C., Celi L.A., Ojikutu B.. “Rural-Urban Differences in Influenza Vaccination Among Adults in the United States, 2018–2019.” Am J Public Health, vol. 112, no. 2, 2022, pp. 304–307.35080958
Hopkins Johns. “COVID-19 Testing: Understanding the “Percent Positive.” August 2020. https://publichealth.jhu.edu/2020/covid-19-testing-understanding-the-percent-positive#:~:text=The%20percent%20positive%20(sometimes%20called,people%20who%20are%20getting%20infected%3F. Accessed May 8, 2023.
Juarez R., Siegal N., Maunakea A.K.. “The Effects of COVID-19 Vaccine Mandates in Hawaii.” Vaccines, vol. 10, no.5, 2022, pp. 773.35632529
Kates J., Tolbert J., and Michaud J.. “The COVID-19 ‘Vaccination Line’: An Update on State Prioritization Plans.” 2021. https://www.kff.org/coronavirus-covid-19/issue-brief/the-covid-19-vaccination-line-an-update-on-state-prioritization-plans/. Accessed March 17, 2023.
Kaiser Family Foundation. “How are States Addressing Racial Equity in COVID-19 Vaccine Efforts?” March 2021.https://www.kff.org/racial-equity-and-health-policy/issue-brief/how-are-states-addressing-racial-equity-in-covid-19-vaccine-efforts/. Accessed April 12, 2023.
Kepka D., Christini K., McGough E., Wagner A., Del Fiol G., Gibson B., Ayres S., "Successful Multi-Level HPV Vaccination Intervention at a Rural Healthcare Center in the Era of COVID-19." Frontiers in Digital Health, vol. 3, 2021. https://doi.org/doi:10.3389/fdgth.2021.719138.
Khanijahani A., Iezadi S., Gholipour K., Azami-Aghdash S., and Naghibi D.. “A Systematic Review of Racial/Ethnic and Socioeconomic Disparities in COVID-19.” International Journal for Equity in Health, vol. 20, no. 1, November 2021.
Kim S.J., Watson K., Khare N., Shastri S., Da Goia Pinto C.L., and Nazir N.T.. "Addressing Racial/Ethnic Equity in Access to COVID-19 Testing through Drive-Thru and Walk-in Testing Sites in Chicago." Medical Research Archives, vol. 9, no. 5, 2021. https://doi.org/doi:10.18103/mra.v9i5.2430.
Kriss J.L., Hung M., Srivastav A., Black C.L., Lindley M.C., Lee J.T., Koppaka R., “COVID-19 Vaccination Coverage, by Race and Ethnicity — National Immunization Survey Adult COVID Module, United States, December 2020–November 2021.” Morbidity and Mortality Weekly Report, vol. 71, no. 23, 2022, pp. 757–763.35679179
Pirtle Laster, Whitney N. “Racial Capitalism: A Fundamental Cause of Novel Coronavirus (COVID-19) Pandemic Inequities in the United States.” Health Education & Behavior, vol. 47, no. 4, 2020, pp. 504–508.32338071
Landes S.D., Turk M.A., Formica M.K., McDonald K.E., Stevens J.D.. “COVID-19 outcomes among people with intellectual and developmental disability living in residential group homes in New York State.” Disabil Health J vol.13, 2020.
Leibowitz A., Livaditis L., Daftary G., Pelton-Cairns L., Regis C., and Taveras E.. "Using Mobile Clinics to Deliver Care to Difficult-to-Reach Populations: A COVID-19 Practice We Should Keep." Preventive Medicine Reports, vol. 24, 2021. https://doi.org/doi:10.1016/j.pmedr.2021.101551.
Leifheit K.M., Chaisson L.H., Medina J.A., Wahbi R.N., Shover C.L.. “Elevated Mortality Among People Experiencing Homelessness With COVID-19.” Open Forum Infect Dis. Vol. 8, no. 7, 2021, pp, ofab301.34291120
Leuchter R.K., Jackson N., Mafi J., Sarksian C., and Geffen D.. “Association Between Covid-19 Vaccination and Influenza Vaccination Rates.” New England Journal of Medicine, vol. 386, 2022, pp. 2531–2532.35704429
Le-Morawa N., Kunkel A., Darragh J., Reede D., Chidavaenzi N.Z., Lees Y., Hoffman D., "Effectiveness of a COVID-19 Vaccine Rollout in a Highly Affected American Indian Community, San Carlos Apache Tribe, December 2020-February 2021." Public Health Reports, 2022. https://doi.org/doi:10.1177/00333549221120238.
Linder A., Wilson McCarthy V., Green C., Nazdam B., Jamieson D., and Stilt K.. "Animal Markets and Zoonotic Disease in the United States." Harvard Law School, Brooks McCormick Jr. Animal Law & Policy Program and New York University, Center for Environmental & Animal Protection, 2023. https://animal.law.harvard.edu/wp-content/uploads/Animal-Markets-and-Zoonotic-Disease-in-the-United-States.pdf
MacDonald N.E. “Vaccine hesitancy: Definition, scope and determinants.” Vaccine, vol. 33, no. 34, 2015, pp. 4161–4164.25896383
Malone B., Kim E., Jennings R., Pacheco R.A., and Kieu A.. "COVID-19 Vaccine Distribution in a Community with Large Numbers of Immigrants and Refugees." American Journal of Public Health, vol. 112, no. 3, 2022, pp. 393–396. https://doi.org/doi:10.2105/ajph.2021.306608.35196045
Manuel D.G., Delatolla R., Fisman D.N., Fuzzen M., Graber T., Katz G.M., Kim J., “The Role of Wastewater Testing for SARS-CoV-2 Surveillance.” Science Briefs of Ontario COVID-19 Science Advisory Table, vol. 2, no. 40, 2021.
Marcell L., Dokania E., Navia I., Baxter C., Crary I., Rutz S., Soto Monteverde M.J., "One Vax Two Lives: A Social Media Campaign and Research Program to Address COVID-19 Vaccine Hesitancy in Pregnancy." American Journal of Obstetrics and Gynecology, vol. 227, no. 5, 2022, pp. 685–685. https://doi.org/doi:10.1016/j.ajog.2022.06.022.35752303
March of Dimes. “March of Dimes Launches Campaign to End Health Disparities in Routine Immunizations.” November 18, 2021. https://www.marchofdimes.org/about/news/march-dimes-launches-campaign-to-end-health-disparities-routine-immunizations. Accessed April 12, 2023.
Marquedant K. “Study Finds Racial and Ethnic Disparities in COVID-19 Vaccine Uptake.” February 1, 2022. https://www.massgeneral.org/news/press-release/study-finds-racial-and-ethnic-disparities-in-covid-19-vaccine-uptake. Accessed April 12, 2023.
Marquez C., Kerkhoff A.D., Naso J., Contreras M. G., Castellanos Diaz E., Rojas S., Peng J., "A Multi-Component, Community-Based Strategy to Facilitate COVID-19 Vaccine Uptake Among Latinx Populations: From Theory to Practice." PloS One, vol. 16, no. 9, 2021a. https://doi.org/doi:10.1371/journal.pone.0257111.
Marquez N., Ward J.A., Parish K., Saloner B., Dolovich S.. “COVID-19 Incidence and Mortality in Federal and State Prisons Compared With the US Population, April 5, 2020, to April 3, 2021.” JAMA, vol. 326, no. 18, 2021b, pp. 1865–1867.34613335
Massachusetts Department of Public Health. “Baker-Polito Administration Launches Targeted Outreach Initiative in 20 Hardest Hit Communities to Increase Equity in COVID-19 Vaccine Awareness and Access; $1m to Support Vaccination in Historically Underserved Communities.” February 2021. https://archives.lib.state.ma.us/bitstream/handle/2452/843386/on1249030866-2021-02-16.pdf.Accessed January 2023.
Mathur P.K., and Dolgin N.. "Crafting Successful State-Level Public Health Interventions to Vaccinate Homeless Populations During COVID-19." American Journal of Public Health, vol. 112, no. 4, 2022, pp. 601–603. https://doi.org/doi:10.2105/ajph.2022.306719 35319921
Massetti G.M., Jackson B.R., Brooks J.T., Perrine C.G., Reott E., Hall A.J., Lubar D., “Summary of Guidance for Minimizing the Impact of COVID-19 on Individual Persons, Communities, and Health Care Systems — United States, August 2022.” Morbidity and Mortality Weekly Report, vol. 71, no. 33, 2022, pp. 1057–1064.35980866
McCollum C.G., Creger T.N., Rana A.I., Matthews L.T., Baral S.D., Burkholder G.A., Curry W.A., "COVID Community-Engaged Testing in Alabama: Reaching Underserved Rural Populations through Collaboration." American Journal of Public Health, vol. 112, no. 10, 2022, pp. 1399–1403.35952331
McGarry B.E., Gandhi A.D., Syme M., Berry S.D., White E.M., Grabowski D.C.. “Association of State COVID-19 Vaccine Mandates With Staff Vaccination Coverage and Staffing Shortages in US Nursing Homes.” JAMA Health Forum, vol. 29, no.7, 2022, pp. e222363.
Meghani S.H., and Gallagher R.M.. “Disparity vs inequity: toward reconceptualization of pain treatment disparities.” Pain Medicine, vol. 9, no. 5, 2008, pp. 613–623.18777609
Merrick E., Weissman J.P., and Patel S.J.. “Utilizing Google Trends to Monitor Coronavirus Vaccine Interest and Hesitancies.” Vaccine, vol. 40, no. 30, June 2022, pp. 4057–4063.35660035
Miller M.F., Shi M., Motsinger-Reif A., Weinberg C.R., Miller J.D., and Nichols E.. “Community-Based Testing Sites for SARS-CoV-2 — United States, March 2020–November 2021.” Morbidity and Mortality Weekly Report, vol. 70, 2021, pp. 1706–1711.34882655
Miller S., Wherry L.R., and Mazumder B.. “Estimated Mortality Increases During the COVID-19 Pandemic by Socioeconomic Status, Race, and Ethnicity.” Health Affairs, vol. 40, no. 8, 2021.
Molling P.E., Holst T.T., Anderson B.G., Fitzgerald K., Eddy M., Weber B.D., Schwan B., "Drive-Through Satellite Testing: An Efficient Precautionary Method of Screening Patients for SARS-CoV-2 in a Rural Healthcare Setting." Journal of Primary Care & Community Health, vol. 11, 2020, pp. 1–6.
Moore D., Mansfield L.N., Onsomu E. O., and Caviness-Ashe N.. "The Role of Black Pastors in Disseminating COVID-19 Vaccination Information to Black Communities in South Carolina." International Journal of Environmental Research and Public Health, vol. 19, no. 15, 2022.
Morello L., and Lim D.. “FDA Authorizes Pfizer Vaccine for Kids 12 to 15.” Politico, 2021. https://www.politico.com/news/2021/05/10/vaccine-pfizer-teens-authorized-486677#:~:text=The%20Food%20and%20Drug%20Administration%20said%20Pfizer%27s%20coronavirus,by%20the%20time%20the%20next%20school%20year%20starts. Accessed March 16, 2023.
Mullin S., Wang S., Morozova I., Berenson J., Asase N., Rodney D. J., Arthur S., "Testing Communication Concepts on COVID-19 Contact Tracing Among Black and Latinx/Hispanic People in the United States." Journal of Racial and Ethnic Health Disparities, vol. 9, no. 6, 2022, pp. 2300–2316.35391715
Muric G., Wu Y., and Ferrara E.. “COVID-19 Vaccine Hesitancy on Social Media: Building a Public Twitter Data Set of Antivaccine Content, Vaccine Misinformation, and Conspiracies.” JMIR Publications, vol. 7, no. 11, 2021.
National Academies of Sciences, Engineering, and Medicine. Framework for Equitable Allocation of COVID-19 Vaccine. Washington, DC: The National Academies Press, 2020.
National Foundation for Infectious Diseases. “Keep Up the Rates.” 2021. https://www.nfid.org/keep-up-the-rates/. Accessed January 2023.
National Governors Association. “Prioritizing Equity in Covid-19 Vaccinations: Promising Practices from States to Reduce Racial and Ethnic Disparities.” March 2021. https://www.nga.org/wp-content/uploads/2021/03/Duke-NGA_Equity-in-Covid-19-Vaccination.pdf. Accessed January 2023.
National Institute of Biomedical Imaging and Bioengineering. “NIH Mobilizes National Innovation Initiative for COVID-19 Diagnostics.” 2020. https://www.nibib.nih.gov/news-events/newsroom/nih-mobilizes-national-innovation-initiative-covid-19-diagnostics. Accessed March 16, 2023.
National Institutes of Health (NIH). “NIH Expands Research to Improve COVID-19 Testing Among Underserved and Vulnerable Populations.” November 2020. https://www.nih.gov/news-events/news-releases/nih-expands-research-improve-covid-19-testing-among-underserved-vulnerable-populations. Accessed January 2023.
NIH. “NIH to Assess and Expand COVID-19 Testing for Underserved Communities.” September 2020. https://www.nih.gov/news-events/news-releases/nih-assess-expand-covid-19-testing-underserved-communities#:~:text=September%2030%2C%202020-,NIH%20to%20assess%20and%20expand%20COVID%2D19%20testing%20for%20underserved,for%20underserved%20and%20vulnerable%20populations. Accessed January 2023.
NIH. “RADx-UP.” 2020. https://radx-up.org/. Accessed January 2023.
NIH. “About CEAL.” 2023. https://covid19community.nih.gov/about. Accessed April 2023.
Nayak A., Islam S.J., Mehta A., Ko Y.A., Patel S.A., Goyal A., Sullivan S., “Impact of Social Vulnerability on COVID-19 Incidence and Outcomes in the United States.” medRxiv [preprint], April 2020. https://doi.org/10.1101/2020.04.10.20060962.
Ndugga N., Hill L., Artiga S.. “COVID-19 Cases and Deaths by Race/Ethnicity: Current Data and Changes Over Time.” 2022. https://www.kff.org/coronavirus-covid-19/issue-brief/covid-19-cases-and-deaths-by-race-ethnicity-current-data-and-changes-over-time/. Accessed April 12, 2023.
Neely J., Eddins A., Lesure N., Dee D., Real R., Singer R., Crooks N., "Privacy, or the Lack Thereof, and Its Implications for Dignity in Mobile COVID-19 Testing." SAGE Open Nursing, vol. 7, 2021. https://doi.org/doi:10.1177/23779608211029096.
New York State Department of Health. “New York State’s Covid-19 Vaccination Program: Executive Summary.” October 2020. https://www.governor.ny.gov/sites/default/files/atoms/files/NYS_COVID_Vaccination_Program_Book_10.16.20_FINAL.pdf. Accessed January 2023.
Nguyen K.H., Anneser E., Toppo A., Allen J.D., Parott J.S., and Corlin L.. “Disparities in National and State Estimates of COVID-19 Vaccination Receipt and Intent to Vaccinate by Race/Ethnicity, Income, and Age Group Among Adults ≥ 18 Years, United States.” Vaccine, vol. 40, no. 1, January 2022, pp.107–113.34852946
NYU Silver School of Social Work. “Dr. Marya Gwadz Awarded NIH Grant to Support COVID-19 Testing in Underserved and Vulnerable Populations.” January 2022. https://socialwork.nyu.edu/news/2022/dr-marya-gwadz-awarded-nih-grant-to-support-covid-19-testing-in-.html. Accessed January 2023.
Ohio Department of Health. “Get Tested for COVID-19.” https://coronavirus.ohio.gov/resources/general-resources/get-tested-for-covid-19. Accessed January 2023.
O’Neil S., and Wesley D.B.. “A Clear Pathway to Progress and a Framework for Advancing Health Equity.” 2021. https://www.mathematica.org/blogs/a-clear-pathway-to-progress-and-a-framework-for-advancing-health-equity. Accessed March 20, 2023.
Oregon Health Authority. “COVID-19 Vaccine Information for Providers.” https://www.oregon.gov/oha/PH/PREVENTIONWELLNESS/VACCINESIMMUNIZATION/IMMUNIZATIONPROVIDERRESOURCES/Pages/COVIDvaccine.aspx. Accessed January 2023.
Osibanjo O., Benkstein K., Slater J., and Shah A.. "The Role of Managed Care Clinical Pharmacists in Improving COVID-19 Vaccination Rates for Culturally Specific Medicaid Populations." Journal of the American College of Clinical Pharmacy, vol. 5, no. 8, 2022, pp. 812–820. https://doi.org/doi:10.1002/jac5.1662.35937306
Murthy Patel. Murthy B., Zell E, Kirtland K., Jones-Jack N., Harris L., Sprague C. “Impact of the COVID-19 pandemic on administration of selected routine childhood and adolescent vaccinations—10 U.S. jurisdictions, March–September 2020.” Morbidity and Mortality Weekly Report, vol. 70, 2021, pp. 840–845.34111058
PBS News Hour. “Updated COVID-19 Booster Shots Are Now Available. Here’s What You Need to Know.” 2022. https://www.pbs.org/newshour/health/updated-covid-19-booster-shots-are-now-available-heres-what-you-need-to-know#:~:text=On%20Sept.%201%2C%202022%2C%20the%20Centers%20for%20Disease,Drug%20Administration%E2%80%99s%20emergency%20use%20authorization%20of%20the%20shots. Accessed March 16, 2023.
Peteet B., Watts V., Tucker E., Brown P., Hanna M., Saddlemire A., Rizk M., "Faith, Fear, and Facts: A COVID-19 Vaccination Hesitancy Intervention for Black Church Congregations." Vaccines, vol. 10, no. 7, 2022. https://doi.org/doi:10.3390/vaccines10071039.
Pfizer. “Addressing Disproportionate Childhood Vaccination.” 2023. https://www.pfizer.com/news/articles/addressing_disproportionate_childhood_vaccination. Accessed April 12, 2023.
Pond E.N., Rutkow L., Blauer B., Alonso A.A., de Lis S.B., and Nuzzo J.B.. “Research Brief Report: Disparities in SARS-CoV-2 Testing for Hispanic/Latino Populations: An Analysis of State-Published Demographic Data.” Journal of Public Health Management and Practice, vol. 28, no. 4, 2022, pp. 330.35149661
Public Health—Seattle and King County. “King County Unified Regional Strategy: COVID-19 Vaccine Delivery.” April 2021.https://kingcounty.gov/~/media/depts/health/communicable-diseases/documents/C19/king-county-strategy-for-vaccine-delivery.ashx?la=en. Accessed January 2023.
Pullan S., and Dey M.. “Vaccine Hesitancy and Anti-Vaccination in the Time of COVID-19: A Google Trends Analysis.” Vaccine, vol. 39, no. 14, April 2021, pp. 1877–1881. https://doi.org/10.1016/j.vaccine.2021.03.019 33715904
Diagnostics Quest. “Quest Diagnostics Partners with CDC to Extend $0 Out-of-pocket COVID-19 Diagnostic Testing to Underserved Communities.” 2022. https://newsroom.questdiagnostics.com/2022-07-07-Quest-Diagnostics-Partners-with-CDC-to-Extend-0-Out-of-pocket-COVID-19-Diagnostic-Testing-to-Underserved-Communities. Accessed March 16, 2023.
Rader B., Gertz A., Iuliano A.D., Gilmer M., Wronski L., Astley C.M., Sewalk K. “Use of At-Home COVID-19 Tests—United States, August 23, 2021–March 12, 2022.” Morbidity and Mortality Weekly Report, vol. 71, no. 13, 2022, pp. 489. http://dx.doi.org/10.15585/mmwr.mm7113e1 35358168
Reitsma M.B., Goldhaber-Fiebert J.D., and Salomon J.A.. “Quantifying and Benchmarking Disparities in COVID-19 Vaccination Rates by Race and Ethnicity.” JAMA Network Open, vol. 4, no. 10, October 2021, p. e2130343. http://jamanetwork.com/article.aspx?doi=10.1001/jamanetworkopen.2021.30343.34668949
Media Relias. "Reproductive Health Organizations Help Vaccinate Patients, Communities: Planned Parenthood Targets Minority Populations." Contraceptive Technology Update, vol. 42, no. 8, 2021, pp. 1–4.
Rockfeller Foundation. “The Rockefeller Foundation Partners With iHealth Labs, CareEvolution, Amazon, and Six State Health Departments to Deliver Free Covid-19 Tests to Vulnerable Communities.” January 2022. https://www.rockefellerfoundation.org/news/the-rockefeller-foundation-partners-with-ihealth-labs-careevolution-amazon-and-six-state-health-departments-to-deliver-free-covid-19-tests-to-vulnerable-communities/. Accessed January 2023.
Romano S.D., Blackstock A.J., Taylor E.V., Felix S.E., Adjeiet S., Singleton C., Fuld J., “Trends in Racial and Ethnic Disparities in COVID-19 Hospitalizations, by Region—United States, March–December 2020.” Morbidity and Mortality Weekly Report, vol. 70, April 2021, pp.560–565.33857068
Rosen A.D., Senturia A., Howerton I., Kantrim E.U., Evans V., Malluche T., Miller J., "A COVID-19 Vaccination Program to Promote Uptake and Equity for People Experiencing Homelessness in Los Angeles County." American Journal of Public Health, vol. 113, no. 2, 2023, pp. 170–174. https://doi.org/doi:10.2105/ajph.2022.307147.36455191
Roth Ella. “State Strategies to Increase COVID-19 and Routine Immunizations in Advance of Back-to-School.” National Academy for State Health Policy blog, August 23, 2021.
Rubin-Miller L., Alban C., Artiga S., and Sullivan S.. “COVID-19 Racial Disparities in Testing, Infection, Hospitalization, and Death: Analysis of Epic Patient Data.” 2020. https://www.kff.org/coronavirus-covid-19/issue-brief/covid-19-racial-disparities-testing-infection-hospitalization-death-analysis-epic-patient-data/. Accessed March 20, 2023.
Ryerson A.B., Rice C.E., Hung M., Patel S.A., Weeks J.D., Kriss J.L., Peacock G., “Disparities in COVID-19 Vaccination Status, Intent, and Perceived Access for Noninstitutionalized Adults, by Disability Status — National Immunization Survey Adult COVID Module, United States, May 30–June 26, 2021.” Morbidity and Mortality Weekly Report, vol. 70, no. 39, 2021, pp. 1365–1371.34591826
Saelee R., Zell E., Murthy B.P., Castro-Roman P., Fast H., Meng L., Shaw L., “Disparities in COVID-19 Vaccination Coverage Between Urban and Rural Counties — United States, December 14, 2020–January 31, 2022.” Morbidity and Mortality Weekly Report, vol. 71, no. 9, 2022, pp. 335–340.35239636
Saloner B., Parish K., Ward J.A., DiLaura G., Dolovich S.. “COVID-19 Cases and Deaths in Federal and State Prisons.” JAMA. Vol. 324, no.6, pp. 602–603. doi:10.1001/jama.2020.12528
Santoli J.M., Lindley M.C., DeSilva M.B., Kharbanda E.O., Daley M.F., Galloway L., Gee J., “Effects of the COVID-19 Pandemic on Routine Pediatric Vaccine Ordering and Administration — United States, 2020.” Morbidity and Mortality Weekly Report, vol. 69, no. 19, May 15, 2020, pp. 591–593. https://www.cdc.gov/mmwr/volumes/69/wr/mm6919e2.htm. Accessed January 2023.32407298
Schnirring L. “Early US Indicators Show Ongoing Slight Rise in COVID-19 Activity.” July 21, 2023. Early US indicators show ongoing slight rise in COVID-19 activity | CIDRAP (umn.edu). Accessed August 1, 2023.
Sears G., Tutt M., Sabo S., Lee N., Teufel-Shone N., Baca A., Bennett M., "Building Trust and Awareness to Increase Az Native Nation Participation in COVID-19 Vaccines." International Journal of Environmental Research and Public Health, vol. 20, no. 1, 2022.
Seither R., Laury J., Mugerwa-Kasujja A., Knighton C.L., and Black C.L.. “Vaccination Coverage with Selected Vaccines and Exemption Rates Among Children in Kindergarten — United States, 2020–21 School Year.” Morbidity and Mortality Weekly Report, vol. 71, 2022, pp. 561–568.35446828
Seither R., Calhoun K., Bidemi Yusuf O., Dramann D., Mugerwa-Kasujja A., Knighton C.L., and Black C.L.. “Vaccination Coverage with Selected Vaccines and Exemption Rates Among Children in Kindergarten — United States, 2021–22 School Year.” Morbidity and Mortality Weekly Report, vol. 72, 2023, pp. 26–32. 2023.36634005
Servick K. “’Huge Hole' in COVID-19 Testing Data Makes It Harder to Study Racial Disparities.” Science, July 10, 2020. https://www.science.org/content/article/huge-hole-covid-19-testing-data-makes-it-harder-study-racial-disparities. Accessed January 2023.
Simmons A., Chappel A., Kolbe A.R., Bush L., and Sommers B.D.. “Health Disparities by Race and Ethnicity During the COVID-19 Pandemic: Current Evidence and Policy Approaches.” March 6, 2021. Available at https://aspe.hhs.gov/sites/default/files/migrated_legacy_files//199516/covid-equity-issue-brief.pdf. Accessed April 11, 2023.
Singler L., Uhlenbrauck G., Corbie-Smith G., Richmond A., Hattem A., Linney K., and Cohen-Wolkowiez M.. "Say Yes! COVID Test: A Health Communication Campaign to Encourage Use of Rapid, at-Home Antigen.” Inquiry, vol. 60, 2023. https://doi.org/10.1177/00469580221146046.
Skolnik A., Bhatti A., Larson A., Mitrovich R.. “Silent Consequences of COVID-19: Why Iťs Critical to Recover Routine Vaccination Rates Through Equitable Vaccine Policies and Practices.” Ann Fam Med, vol. 19, no. 6, 2021, pp. 527–531.34376387
Smith A.R., DeVies J., Caruso E., Radhakrishnan L., Sheppard M., Stein Z., Calanan R.M., “Emergency Department Visits for COVID-19 by Race and Ethnicity—13 States, October–December 2020.” Morbidity and Mortality Weekly Report, vol. 70, no. 15, April 2021, pp.566–569.33857062
Sparks G., Kirzinger A., and Brodie M.. “KFF COVID-19 Vaccine Monitor: Profile of the Unvaccinated.” 2021. https://www.kff.org/coronavirus-covid-19/poll-finding/kff-covid-19-vaccine-monitor-profile-of-the-unvaccinated/. Accessed March 20, 2023.
Stokley S. “National and State-Level HPV Vaccination Coverage.” 2022. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2022-06-22-23/02-HPV-Stokley-508.pdf. Accessed March 29, 2023.
Tan T.Q., Kullar R., Swartz T.H., Mathew T.A., Piggott D.A., and Berthaud V.. “Location Matters: Geographic Disparities and Impact of Coronavirus Disease 2019.” Journal of Infectious Diseases, vol. 222, no. 12, 2020, pp. 1951–1954.32942299
The Covid Tracking Project. “Long-Term-Care COVID Tracker.” 2021. https://covidtracking.com/nursing-homes-long-term-care-facilities. Accessed April 12, 2023.
Thomson A., Robinson K., and Vallée-Tourangeau G.. “The 5As: A practical taxonomy for the determinants of vaccine uptake.” Vaccine, vol. 34, no. 8, 2016, pp. 1018–1024.26672676
Tsai T.C., Jacobson B.H., Orav E.J., Jha A.K.. “Association of community-level social vulnerability with US acute care hospital intensive care unit capacity during COVID-19.” Healthc (Amst) vol. 10, no.1, pp. 100611.
UC Davis Health. “UC Davis to Offer Free COVID-19 Testing for Central Valley Farmworkers.” October 1, 2020. https://health.ucdavis.edu/news/headlines/grant-allows-uc-davis-to-test-farmworkers-for-covid-19-at-their-workplace/2020/09. Accessed January 2023.
UNC Health and UNC School of Medicine. “Health Equity Research, and Partners Receive $80 million NIH Grant to Expand COVID-19 Testing.” October 1, 2020. https://news.unchealthcare.org/2020/10/duke-clinical-research-institute-unc-center-for-health-equity-research-and-partners-receive-80-million-nih-grant-to-expand-covid-19-testing/. Accessed April 12, 2023.
University of Utah. “New Initiatives Awarded $4.7 Million to Encourage COVID-19 Testing in Underserved Communities and Schools.” April 2022. https://healthcare.utah.edu/publicaffairs/news/2022/04/4-scaleup-ii. Accessed April 12, 2023.
Urban Institute. “Data Are Essential to Prioritizing Racial and Ethnic Equity in COVID-19 Vaccination.” February 2021. https://www.urban.org/urban-wire/data-are-essential-prioritizing-racial-and-ethnic-equity-covid-19-vaccination. Accessed April 12, 2023.
U.S. Department of Agriculture. “Emergency Rural Health Care Grants Track 1: Recovery Grants Application Guide.” August 2021. https://www.rd.usda.gov/sites/default/files/508_rd_erhctrackoneapplicationguide_091721.pdf. Accessed April 12, 2023.
U.S. Department of Health and Human Services (HHS). “Join the COVID-19 Community Corps!” 2021a. https://wecandothis.hhs.gov/covidcommunitycorps#:~:text=The%20Corps%2C%20launched%20in%20April,health%2C%20communities%2C%20and%20economy. Accessed April 12, 2023.
HHS. “Biden Administration Announces Actions to Expand COVID-19 Testing.” 2021b. https://public3.pagefreezer.com/content/HHS.gov/18-02-2021T04:26/https:/www.hhs.gov/about/news/2021/02/17/biden-administration-announces-actions-expand-covid-19-testing.html. Accessed March 16, 2023.
HHS. “COVID-19 Testing and Diagnostics Working Group (TDWG).” 2021c. https://www.hhs.gov/coronavirus/testing/testing-diagnostics-working-group/index.html. Accessed April 12, 2023.
HHS. “Featured Priority: Catch-Up Immunization.” 2021d. https://www.hhs.gov/vaccines/featured-priorities/catch-up-vaccination/index.html. Accessed April 12, 2023.
HHS. “HHS Announces New $350 Million Initiative to Increase COVID-19 Vaccinations.” November 2022. https://www.hhs.gov/about/news/2022/11/22/hhs-announces-new-350-million-initiative-increase-covid-19-vaccinations.html. Accessed April 12, 2023.
U.S. Department of Health and Human Services Office of Minority Health. “HHS Announces Partnership with Morehouse School of Medicine to Fight COVID-19 in Racial and Ethnic Minority and Vulnerable Communities.” June 23, 2020. https://minorityhealth.hhs.gov/omh/Content.aspx?ID=17500&lvl=2&lvlid=8. Accessed April 12, 2023.
U.S. Department of Housing and Urban Development. “CDBG-CV Program.” 2021. https://www.hudexchange.info/programs/cdbg-cv/. Accessed April 12, 2023.
U.S. Government Accountability Office. “Federal Efforts to Provide Vaccines to Racial and Ethnic Groups.” February 2022. https://www.gao.gov/products/gao-22-105079. Accessed April 4, 2023.
Venegas-Murillo A.L., Bazargan M., Grace S., Cobb S., Vargas R., Givens S., Li-Sarain S., "Mitigating COVID-19 Risk and Vaccine Hesitancy Among Underserved African American and Latinx Individuals with Mental Illness through Mental Health Therapist-Facilitated Discussions" Journal of Racial and Ethnic Health Disparities, 2022, pp. 1–13.
Wang Q.Q., Kaelber D.C., Xu R., Volkow N.D.. “COVID-19 risk and outcomes in patients with substance use disorders: analyses from electronic health records in the United States.” Mol Psychiatry. vol. 26, no. 1, 2021, pp. 30–39.32929211
Wasfy J.H., Hidrue M.K., Rockett H., Cafiero-Fonseca E.T., Ferris T.G., and del Carmen M.G.. “Socioeconomic and Demographic Characteristics of Both Inpatients and Outpatients with Positive Testing for SARS-CoV-2.” Journal of General Internal Medicine, vol. 36, 2021, pp. 2522–2524.34105060
Washington T.A., Glenn W., Barreras J., and Ramos A.. "COVID-19 Prevention Program to Encourage Vaccination Uptake Among Substance-Using Black and Latinx Sexual Minority Men." Health and Social Work, vol. 47, no. 4, 2022, pp. 301–304. https://doi.org/doi:10.1093/hsw/hlac022.36099156
Webb Hooper M., Nápoles A.M., and Pérez-Stable E.J.. “COVID-19 and Racial/Ethnic Disparities.” Journal of the American Medical Association, vol. 323, no. 24, May 2020, pp. 2466–2467. http://jamanetwork.com/article.aspx?doi=10.1001/jama.2020.8598.32391864
Weixel N. “CDC adds COVID vaccine to routine immunization schedule for kids, adults.” February 9, 2023.https://news.yahoo.com/cdc-adds-covid-vaccine-routine-230629686.html?guccounter=1&guce_referrer=aHR0cHM6Ly93d3cuYmluZy5jb20v&guce_referrer_sig=AQAAANQVElXrSkCEWhaGp-B4cs71XSTxO2B6mmUMNCMCzup3cXO4zfigvs-A27O74kuTFT-VMpjSIqFPCXrV9iZqhXEKSlKQNWDa_pc9BChBTyJGJ-3jre8sYz4J1xCREBw1frqI5URhfi75ZI-CLZXzcDPQLqL80kreiIiZscaCoQkw. Accessed May 2, 2023.
Whanger S., Davis S.K., Kemper E., Heath-Granger J., and Hodder S.L.. "Novel Strategies to Increase COVID-19 Testing among Underserved and Vulnerable Populations in West Virginia." American Journal of Public Health, vol. 112, 2022, pp. S892–S895.36265093
White House. “Fact Sheet: Biden Administration Announces Historic $10 Billion Investment to Expand Access to COVID-⁠19 Vaccines and Build Vaccine Confidence in Hardest-Hit and Highest-Risk Communities.” 2021a. https://www.whitehouse.gov/briefing-room/statements-releases/2021/03/25/fact-sheet-biden-administration-announces-historic-10-billion-investment-to-expand-access-to-covid-19-vaccines-and-build-vaccine-confidence-in-hardest-hit-and-highest-risk-communities/. Accessed April 2023.
White House. “Fact Sheet: President Biden to Announce All Americans to be Eligible for Vaccinations by May 1, Puts the Nation on a Path to Get Closer to Normal by July 4th.” 2021b. https://www.whitehouse.gov/briefing-room/statements-releases/2021/03/11/fact-sheet-president-biden-to-announce-all-americans-to-be-eligible-for-vaccinations-by-may-1-puts-the-nation-on-a-path-to-get-closer-to-normal-by-july-4th/. Accessed March 29, 2023.
Whitener K., and Corcoran A.. “Decline in Routine Childhood Vaccinations Puts Children, Families and Communities at Risk of Outbreak.” 2021. https://ccf.georgetown.edu/2021/07/15/decline-in-routine-childhood-vaccinations-puts-children-families-and-communities-at-risk-of-outbreak/. Accessed April 12, 2023.
Williams E., Kates J., and Rudowitz R.. “Update on Children’s COVID-19 and Routine Vaccination Trends Heading into Winter and as Respiratory Viruses Surge.” 2022. https://www.kff.org/policy-watch/update-on-childrens-covid-19-and-routine-vaccination-trends-heading-into-winter-and-as-respiratory-viruses-surge/. Accessed March 29, 2023.
Willis D. E., Montgomery B. E., Selig J. P., Andersen J. A., Shah S. K., Li J., ... P. A. and McElfish. “COVID-19 vaccine hesitancy and racial discrimination among US adults.” Preventive Medicine Reports, vol. 31, no. 102074. 2023.
Winterbauer E., Levy P.D., Calhoun D., Elwell T., Fishbein E., Donohue S., and Little J.. "Qualitative Review of Promising Practices for Testing Vulnerable Populations at Off-Site COVID-19 Testing Centers." Healthcare, vol. 9, no. 1, 2021.
World Health Organization. “Strategy to Achieve Global Covid-19 Vaccination by Mid-2022.” n.d. https://cdn.who.int/media/docs/default-source/immunization/covid-19/strategy-to-achieve-global-covid-19-vaccination-by-mid-2022.pdf. Accessed April 12, 2023.
World Health Organization (WHO). “A Conceptual Framework for Action on the Social Determinants of Health.” 2010. https://www.who.int/publications/i/item/9789241500852. Accessed March 20, 2023.
World Health Organization. “COVID-19 Pandemic Fuels Largest Continued Backslide in Vaccinations in Three Decades.” July 2022. https://www.who.int/news/item/15-07-2022-covid-19-pandemic-fuels-largest-continued-backslide-in-vaccinations-in-three-decades. Accessed April 12, 2023.
World Health Organization. “Social determinants of health.” 2023. Available at https://www.who.int/health-topics/social-determinants-of-health#tab=tab_1. Accessed May 8, 2023.